# Appendix C Background Information for Zinc

## C.1 Toxicokinetics

Zinc is absorbed through the respiratory system and skin as evidenced by increased blood, urine, and tissue levels, but quantitative estimates of respiratory or dermal absorption were not located. The absorption of zinc from the gastrointestinal tract has been studied extensively. Absorption from the gastrointestinal tract is homeostatically regulated; 20–30% of ingested zinc is absorbed under normal physiological conditions. Intestinal absorption is saturable, suggesting that it may be enzyme- or carrier-mediated. Alternatively, it has been proposed that excess zinc ions neutralize membrane charges, interfering with membrane binding and subsequent uptake into the mucosal cells. Zinc induces metallothionein synthesis in the mucosal cells. The metallothionein may contribute to zinc homeostasis by sequestering some zinc in the intestinal mucosal cells until the cells are sloughed and excreted in the feces. Dietary constituents influence zinc absorption, with protein facilitating absorption and fiber or calcium decreasing absorption. In the plasma, the carrier for zinc is primarily albumin, with lesser amounts of zinc bound to "α_2_-macroglobulin and amino acids. Zinc is initially concentrated in the liver and then distributed throughout the body, with high concentrations in the prostate, retina, sperm, gastrointestinal tract, kidney, brain, skin, lung, heart, and pancreas. The highest percentages of the body burden of zinc are found in muscle (≈63%) and bone (≈28%). Zinc is excreted primarily in the feces; fecal excretion includes unabsorbed zinc, zinc excreted in the bile, and zinc in exfoliated intestinal mucosal cells. In addition, zinc is excreted in the urine and in sweat (ATSDR 1994). Zinc does not appear to accumulate in the body with age (Walsh et al. 1994).

One limitation of dose or exposure data for both human and animal studies is that the contribution to body burden from the diet generally is not precisely known, and frequently is not even discussed in the studies. Zinc is an essential element that occurs naturally in the human diet, and is included in all commercial animal chows, but levels of intake are often not precisely known, even for animal diets. Therefore, reported doses in experimental studies discussed in the following sections are for the intentionally administered zinc, unless otherwise specified, consistent with ATSDR (1994).

## C.2 Health Effects

Zinc is an essential element for humans and animals due to its role as a constituent of metalloenzymes such as alcohol dehydrogenase, alkaline phosphatase, carbonic anhydrase, Cu/Zn superoxide dismutase, and DNA and ribonucleic acid (RNA) polymerases, as a constituent of zinc-finger regions of transcription factors, and as a constituent of or requirement for ALAD. Thus, zinc is required for cell division, metabolism, growth, and repair (ATSDR 1994; Dreosti 2001; IRIS 2001; NRC 1989). Zinc occurs in only one oxidation state, Zn(II), and tends to have a stabilizing role in its binding with sulfhydryl groups and maintenance of protein conformation (Bremner and Beattie 1995). Zinc released from vesicles in presynaptic terminals of certain glutaminergic neurons is thought to modulate postsynaptic NMDA receptors for glutamate (Sandstead et al. 2000). Zinc deficiency causes loss of appetite, growth retardation, dermatitis, impaired wound healing, impaired immunological function, hypogonadism (including testicular atrophy), impaired reproductive capacity, depressed mental function, and increased incidences of congenital malformations (ATSDR 1994; Dreosti 2001; IRIS 2001; NRC 1989). The RDA for zinc is 15 mg/day for adolescent and adult males and 12 mg/day for adolescent and adult females, equivalent to ≈0.2 mg/kg/day. The RDA for infants is 5 mg/day, for children is 10 mg/day, and for lactating women is 16–19 mg/day (ranging from ≈0.3 to 0.8 mg/kg/day for these 3 groups) (NRC 1989). The RfD for zinc is 0.3 mg/kg/day, which supplies adequate zinc for adolescents and adults, but not for infants, children, or possibly for lactating women (IRIS 2001).

The NRC (1995) has estimated that zinc requirements in the dry diet for rats are 12 ppm for maintenance and growth and 25 ppm for reproduction including lactation, and for mice are 10 ppm for maintenance and growth and 30 ppm for reproduction including lactation. These estimates represent minimal requirements determined in experiments with purified diets and do not include a margin of safety. The NRC (1995) notes that higher concentrations of zinc—18 ppm for maintenance and growth—are required when the diet includes ingredients that contain phytate, such as soybean meal. The concentrations of zinc in the NIH-07 and NIH-31 natural-ingredient fixed-formula diets provided by the addition of a mineral premix are 18 and 11 ppm, respectively, but additional zinc may be contributed by the other constituents of the diet, and these diets also contain soybean meal and other potential sources of phytate. These diets are used for maintaining rat and mouse breeding colonies at the National Institutes of Health (NIH) and are fed in NTP toxicology and carcinogenicity studies. The concentration of zinc in the commonly used purified diet AIN-76A for rats and in the more recent purified diets AIN-93G and AIN-93M for rats and mice is 30 ppm (NRC 1995). Debilitating deficiency has been reported with zinc concentrations in the diet of <1 ppm and milder deficiency at 2 ppm (Bushnell and Levin 1983). Assuming 100% of the zinc intake is from the diet and using food intake and body weight values for F344 and Sprague-Dawley rats (EPA 1988), levels of 12 and 30 ppm zinc in the diet corresponds to an intake of 2 and 4–5 mg/kg/day for weanling rats, and 1 and 2–3 mg/kg/day for 1-year-old rats and rats in subchronic and chronic studies.

In humans and animals, exposure to zinc at levels above normal dietary requirements causes anemia, gastrointestinal irritation, pancreatic and adrenal abnormalities, impaired immune function, and decreased levels of serum HDL cholesterol, serum ferritin, and erythrocyte superoxide dismutase. Neurological signs have been reported in two human case reports of zinc ingestion and mild histopathological changes were seen in brains of animals treated with zinc, but are not as well documented (ATSDR 1994; IRIS 2001). The worsening of cognition in patients with Alzheimer's disease within two days of starting on zinc supplementation has been noted (Bush et al. 1994), but details, including the supplemental zinc dose, were not published, and no clear evidence has emerged subsequently to indicate that zinc supplementation hastens the progression of Alzheimer’s disease. A later publication by Bush and colleagues (Cuajungco et al. 2000) postulated that the detrimental effects in Alzheimer’s patients may have been due to gastrointestinal effects. Additional effects of high levels of zinc oral intake, seen only in animal studies, included renal effects in rats fed 191 mg Zn/kg/day in the diet for 3 months. Reproductive effects including altered sperm chromatin structure in male rats that received 25 mg/kg/day in the diet for 8 weeks, and developmental effects, including fetal resorption, decreased fetal weight, and increased stillbirths at ≥200 mg/kg/day for 15–36 days. The adverse effects of zinc generally occur at levels of intake elevated by an order of magnitude or more over the RDA or animal dietary requirement (ATSDR 1994; IRIS 2001). Exceptions are the decreases in serum ferritin and erythrocyte superoxide dismutase, a slight decrease in hematocrit (Yadrick et al. 1989), and decreases in HDL cholesterol, which occur at about 5 times the RDA (ATSDR 1994; IRIS 2001).

## C.3 Mechanisms of Action

The anemia and possibly the effect on HDL cholesterol are thought to be caused by zinc-induced copper deficiency. High oral intakes of zinc induce the synthesis of metallothionein in the intestinal mucosal cells, which provides a possible mechanism for zinc induction of copper deficiency. Copper binds to metallothionein with a higher affinity than does zinc and will tend to replace zinc; although some of the metallothionein-bound copper in the intestinal mucosal cells is released to the blood, much of the copper-metallothionein is excreted in the feces when the intestinal mucosal cells are exfoliated. Copper is an essential part of several enzymes including ceruloplasmin, which oxidizes ferrous iron to the ferric form. Because only ferric iron is bound to transferrin and transported to the bone marrow, this transformation is critically important to provide iron for hemoglobin synthesis (ATSDR 1994; Friberg et al. 1986; IRIS 2001). Decreases in another copper metalloenzyme, erythrocyte superoxide dismutase, are considered a more sensitive and reliable indicator of altered copper status than are ceruloplasmin levels or tissue or plasma copper levels (ATSDR 1994; IRIS 2001).

## C.4 Health Guidelines

ATSDR (1994) did not derive inhalation MRLs for any duration of exposure to zinc or an oral MRL for acute exposure to zinc due to lack of suitable studies.

ATSDR (1994) derived an intermediate oral MRL of 0.3 mg/kg/day for zinc based on a LOAEL for hematological effects of 1 mg/kg/day in humans. The LOAEL was determined by adding the estimate of dietary zinc intake for women (20–30 years old) of 9.72 mg Zn/day (0.16 mg/kg/day) from a Food and Drug Administration (FDA) Total Diet study for 1982–1986 (Pennington et al. 1989) to 50 mg Zn/day (0.83 mg/kg/day), the reported supplemental zinc dose associated with decreased hematocrit, serum ferritin, and erythrocyte superoxide dismutase activity in women given this dose of zinc (as zinc gluconate) for 20 weeks (Yadrick et al. 1989). An uncertainty factor of 3 was applied, based on the use of a minimal LOAEL from a study of the most sensitive humans, and the consideration of zinc’s essentiality.

The intermediate oral MRL was adopted as the chronic oral MRL due to the lack of adequate chronic studies. ATSDR (1994) noted that the chronic oral MRL is expected to be without adverse effects from either excess zinc or from nutritional zinc deficiency in healthy, nonpregnant, adult humans ingesting the average American diet.

The NRC (1989) has established an RDA for zinc of 15 mg/day for adolescent and adult males and 12 mg/day for adolescent and adult females, equivalent to ≈0.2 mg/kg/day.

EPA derived an RfD of 0.3 mg/kg/day based on the LOAEL of 1 mg Zn/kg/day for the decrease in erythrocyte superoxide dismutase (indicative of altered copper status) in women due to 50 mg/day of supplemental zinc (Yadrick et al. 1989), combined with the dietary zinc estimates of 9.72 mg/day from the FDA Total Diet Study for 1982–1986 (Pennington et al. 1989).

The National Toxicology Program (NTP 2001) does not list zinc as a substance known or reasonably anticipated to be a human carcinogen and IARC has not published a monograph on the potential carcinogenicity of manganese. EPA (IRIS 2001) has classified zinc in Group D—not classifiable as to human carcinogenicity, based on inadequate data in humans and animals.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

Derivation of a TTD for chronic oral exposure to zinc would be appropriate for sensitive endpoints affected by zinc and one or more of the other chemicals in the lead, manganese, zinc, and copper mixture that is the subject of this Interaction Profile. The relevant endpoints for this mixture include neurological and hematological. Zinc is hematotoxic, and ATSDR has derived an MRL for intermediate oral exposure based on hematological effects, and has adopted that MRL for chronic oral exposure as well.

### Summary (TTD for Zinc)

MRL_HEMATO_ = 0.3 mg/kg/day

## C.6 References

ATSDR. 1994. Toxicological profile for zinc. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Bremner I, Beattie JH. 1995. Copper and zinc metabolism in health and disease: Speciation and interactions. Proc Nutr Soc 54:489–499.8524895
Bush AI, Pettingell WH, Multhaup G, 1994. Rapid induction of Alzheimer Aβ amyloid formation by zinc. Science 265:1464–1467.8073293
Bushnell PJ, Levin ED. 1983. Effects of zinc deficiency on lead toxicity in rats. Neurobehav Toxicol Teratol 5:283–288.6877467
Cuajungco MP, Goldstein LE, Nunomura A, 2000. Evidence that the β-amyloid plaques of Alzheimer's disease represent the redox-silencing and entombment of Aβ by zinc. J Biol Chem 275(26):19439–19442.10801774
Dreosti IE. 2001. Review: Zinc and the gene. Mutat Res 475:161–167.11295161
EPA. 1988. Recommendations for and Documentation of Biological Values for Risk Assessment. U.S. Environmental Protection Agency. NTIS PB88–179874. EPA/600/6–87/008. Cincinnati, OH: Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office.
Friberg L, Nordberg GF, Vouk VB, eds. 1986. Handbook on the toxicology of metals. 2^nd^ ed, Vol. II: Specific Metals. Amsterdam: Elsevier Science Publishing Co. Inc, 242, 668, 671.
IRIS. 2001. Integrated Risk Information System. U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.htm. April 17, 2001.
NRC. 1989. Recommended dietary allowances. 10^th^ ed. Washington, DC: National Academy Press. National Research Council, 205–213, 224–235, 284–285.
NRC. 1995. Nutrient requirements of laboratory animals. 4^th^ ed. Washington, DC: National Academy Press. National Research Council, 11–102.
NTP. 2001. 9^th^ report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services. National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. September 11, 2001.
Pennington JAT, Young BE, Wilson D. 1989. Nutritional elements in U.S. diets: Results form the total diet study, 1982 to 1986. J Am Diet Assoc 89(5):659–664. (As cited in ATSDR 1994).2723289
Sandstead HH, Frederickson CJ, Penland JG. 2000. History of zinc as related to brain function. J Nutr 130:496S–502S.10721938
Walsh CT, Sandstead HH, Prasad AS, 1994. Zinc: Health effects and research priorities for the 1990s. Environ Health Perspect 102(Suppl 2):5–46.
Yadrick MK, Kenney MA, Winterfeldt EA. 1989. Iron, copper, and zinc status: Response to supplementation with zinc or zinc and iron in adult females^1–3^. Am J Clin Nutr 49:145–150.2912000