# Appendix B Background Information for Manganese

Manganese is an element that exists naturally in the environment primarily as salts or oxides. Inorganic manganese in the (II), (III), and (IV) oxidation states are the forms most often encountered in the environment and in the workplace. The available information is insufficient to characterize any differences in toxicity for different manganese oxidation states, and they may be interconvertible in the body (ATSDR 2000).

One limitation of dose or exposure data for both human and animal studies is that the contribution to body burden from the diet generally is not precisely known, and frequently is not even discussed in the studies. Manganese is an essential element that occurs naturally in the human diet, and is included in all commercial animal chows, but levels of intake are often not precisely known, even for animal diets. Therefore, reported doses in experimental studies discussed in the following sections are for the intentionally administered manganese, consistent with the documentation by ATSDR (2000).

## B.1 Toxicokinetics

Absorption of manganese across the gastrointestinal tract typically averages about 3–5% in humans. Absorption may be age-dependent, with infants, especially the premature, retaining a higher proportion of manganese than do adults, although it is uncertain whether the higher retention results from higher absorption or from differences in excretion, or to interactions with iron intake, which is inversely related to manganese absorption. Studies of absorption in animals generally support the human data. Absorption of manganese through the gastrointestinal tract may occur through nonsaturable simple diffusion through the mucosal layer of brush border membranes, or by an active-transport mechanism that is high-affinity, low capacity, and rapidly saturable. Dietary manganese, absorbed into the portal circulation as manganese(II), is bound to "α_2_-macroglobulin or albumin in the plasma. In the liver, the major potion of manganese(II) is secreted into the bile, but some is thought to be oxidized by ceruloplasmin to Mn(III), which enters circulation conjugated with plasma transferrin (ATSDR 2000).

Manganese is a normal component of the body. In humans, highest concentrations of manganese occur in the liver, pancreas, and kidney; lowest concentrations occur in bone and fat. In humans with health conditions (liver disease or dysfunction), excess manganese uptake has occurred following oral exposure. In these cases, excess manganese preferentially accumulated in the basal ganglia, especially the globus pallidus and the substantia nigra. Similar findings, with accumulation of manganese particularly in the globus pallidus, have been reported in humans exposed occupationally (primarily by inhalation). In monkeys given manganese intravenously, accumulation of manganese in the globus pallidus and substantia nigra also was observed. One study in rats demonstrated that continuing exposure to high levels of manganese in the diet resulted in large increases in tissue levels of manganese compared with controls over the first 24 days, but that levels tended to decrease towards the control levels as exposure was continued through 224 days. This finding is thought to be the result of homeostatic mechanisms that lead to decreased absorption and/or increased excretion of manganese when manganese intakes are high. Absorbed manganese is removed from the blood by the liver, where it conjugates with bile and is excreted into the intestine. Although some of manganese in the intestine is reabsorbed through enterohepatic circulation, biliary secretion followed by fecal excretion is the main excretion pathway for gastrointestinally absorbed manganese. Small amounts of manganese are excreted in urine, sweat, and milk. Biliary/fecal excretion in the neonate may be different than in adults, but data for humans indicate greater neonatal excretion, and in animals indicate less neonatal excretion (ATSDR 2000).

## B.2 Health Effects

Manganese is an essential element for humans and animals. Manganese acts both as a constituent of metalloenzymes and as an enzyme activator. Manganese plays a role in bone mineralization, protein and energy metabolism, metabolic regulation, cellular protection from free radicals, and the formation of glycosaminoglycans. Metalloenzymes containing manganese include arginase, pyruvate carboxylase, and Mn superoxide dismutase. Manganese has been shown to activate numerous other enzymes including transferases, decarboxylases, and hydrolases (ATSDR 2000).

The NRC (1989) has established ESADDIs for manganese. The ESADDIs are 2–5 mg/day for adolescents (>11 years) and adults. For children, the ESADDIs are 0.3–0.6 mg/day for infants from birth to 6 months, 0.6–1.0 mg/day for infants from 6 months to 1 year, 1.0–1.5 mg/day for children from 1 to 3 years, 1.5–2.0 mg/day for children from 4 to 6 years, and 2.0–3.0 mg/day for children 7 to 10 years of age.

Effects of manganese deficiency in humans are not well-defined. Limited information indicates that dermatitis, and possibly decreased levels of clotting proteins, decreased serum cholesterol, reddening of black hair, and slowed growth of hair and nails may be consequences of manganese deficiency. Effects of manganese deficiency in animals include impaired growth, skeletal abnormalities, testicular degeneration in males, impaired reproductive function in females, ataxia, altered carbohydrate and lipid metabolism, and increased oxidation of mitochondrial membranes, and reduced high density lipoprotein (HDL) cholesterol (ATSDR 2000)

Exposure to manganese above essential levels can have toxic consequences. Chronic occupational (inhalation) exposure to manganese has been linked to neurological deficits, evidenced as deficits in the ability to perform rapid hand movements and some loss of coordination and balance, and increased mild symptoms such as forgetfulness, anxiety, or insomnia. Very high chronic inhalation exposure, as in former manganese miners, resulted in permanent neurological damage, evidenced by a syndrome of neurological effects called manganism, which includes mask-like facial expression, slow and clumsy gait, fine tremor, and sometimes psychiatric disturbances. Ultimately, patients develop severe hypertonia and muscle rigidity and may be completely disabled. Although some of these symptoms also occur in Parkinson’s disease, the two diseases are different (ATSDR 2000). Unlike Parkinson’s patients, manganism patients generally do not respond to levo-dopa treatment, indicating that degeneration of the receptors and neurons that normally respond to this drug (and to dopamine) may have occurred.

The evidence for neurological effects in humans from oral exposure is more limited, but collectively, the studies suggest an association between ingestion of water and/or food containing increased levels of manganese and adverse neurological effects. Some of the studies reported symptoms and signs similar to those associated with inhalation exposure. Two of the studies focused on children, and associated increased oral intakes of manganese and increased hair manganese with poorer performance in school and on neurobehavioral exams. Other studies have reported higher manganese concentrations in the hair of learning disabled children than in normal children (ATSDR 2000).

Oral neurotoxicity studies in animals have been conducted over a wide range of doses. The lowest dose of manganese tested, 1 mg/kg/day by gavage, produced neuronal degeneration and increased monoamine oxidase in neonatal rats during intermediate duration studies, but no clinical or behavioral signs of neurotoxicity. This dose was considered a serious lowest-observed-adverse-effect level (LOAEL). Neurobehavioral effects were seen in neonatal rats at higher gavage doses of manganese: increased pulse-elicited startle reflex at 11 mg/kg/day and increased spontaneous motor activity at 22 mg/kg/day. In more mature rats given manganese orally in drinking water or food, increased motor activity has been observed at 40 and 140 mg/kg/day, and decreased motor activity at ≥284 mg/kg/day. Many other studies in rodents focused on neurotransmitter levels in the brain. Monkeys given 25 mg/kg/day of manganese by gavage for 18 months developed weakness, muscular rigidity, and neuronal loss and depigmentation of the substantia nigra (ATSDR 2000)

Occupational exposure has resulted in male reproductive effects, including decreased libido and sperm count and viability. Intratracheal instillation of manganese, which may result in gastrointestinal as well as respiratory absorption, resulted in degeneration of the seminiferous tubules and loss of spermatogenesis in rabbits. In young male rodents given relatively high doses of manganese (≥1,050 mg/kg/day), delayed growth and maturation of the testes were reported and appeared to be due to decreased testosterone secretion (ATSDR 2000).

## B.3 Mechanisms of Action

Although the central nervous system is the primary target of manganese toxicity, a mechanism for the neurotoxicity of manganese has not been clearly established. One suggested mechanism is that manganese enhances the autooxidation or turnover of various intracellular catecholamines (dopamine, norepinephrine, epinephrine), leading to increased production of free radicals, reactive oxygen species, and other cytotoxic metabolites, accompanied by a depletion of cellular antioxidant defense mechanisms. Other potential mechanisms include the ability of manganese(II) to substitute for calcium under physiological conditions, the possibility that the dopamine reuptake carrier is linked to a transport mechanism for manganese, inhibition by manganese of brain mitochondrial oxidative phosphorylation, or manganese involvement in complex interactions with other minerals such as iron, copper, selenium, zinc, and calcium (ATSDR 2000). In humans with manganism, neuoropathological changes are detectable in the basal ganglia; the specific area of injury and accumulation of manganese appears to be primarily in the globus pallidus. The substantia nigra is sometimes affected, but generally to a lesser extent. Studies in monkeys given manganese intravenously have produced similar results.

## B.4 Health Guidelines

ATSDR (2000) did not derive acute or intermediate inhalation MRLs manganese due to lack of suitable data.

Using the benchmark dose (BMD) approach, ATSDR (2000) derived a chronic inhalation MRL of 4×10^−5^ mg/m^3^ for manganese based on the 95% lower confidence limit for an increased risk of 10% (BMDL_10_) of 74 μg Mn/m^3^ (respirable dust) for neurobehavioral effects in workers exposed for an average duration of 5.3 years (Roels et al. 1992). The MRL was calculated by converting this concentration from intermittent to continuous exposure (using factors of 5/7 for days per week and 8/24 for hours per day), and applying uncertainty factors of 10 for human variability, 10 for potential differences in toxicity among different manganese forms and other limitations in the database including lack of developmental testing and reproductive testing in females, and a modifying factor of 5 for potential increased susceptibility in children based on differential pharmacokinetics.

ATSDR (2000) did not derive oral MRLs for manganese because no clear threshold level for neurological effects could be determined from the acute and intermediate duration data, and because no firm conclusions were considered possible regarding a critical effect level of chronic intake versus essential dietary levels of chronic intake of manganese. ATSDR (2000) derived a provisional guidance value for total dietary intake of 0.07 mg Mn/kg/day, based on the upper end of the ESADDI range (5 mg/day, divided by 70 kg, the weight of an adult), to be used in ATSDR human health assessments. The chronic inhalation MRL for manganese is based on neurological effects.

The NRC (1989) concluded that given the apparent lack of manganese deficiency in adults, the U.S. dietary intakes of manganese (2.2–2.7 mg/day for women and men, respectively) appear to satisfy the need for this element. Therefore, the NRC established an estimated safe and adequate daily dietary intake for manganese of 2.0–5.0 mg/day for adults. An RDA could not be determined because data were insufficient to determine the manganese needs of heathy persons.

EPA (IRIS 2001) derived an RfC of 5x10^−5^ mg/m^3^ for manganese based on a LOAEL_HEC_ of 0.05 mg Mn/m^3^ for neurobehavioral effects in workers exposed to manganese for an average of 5.3 years (Roels et al. 1992). The uncertainty factor used in this derivation was 1,000 (10 for human variability, 10 for the use of a LOAEL, and 10 for database limitations including the less-than chronic exposure period and the lack of developmental data, and potential differences in the toxicity of various forms of manganese).

EPA (IRIS 2001) derived a chronic RfD of 0.14 mg Mn/kg/day for manganese based on a NOAEL of 0.14 mg/kg/day for central nervous system effects, and an uncertainty factor of 1. This NOAEL was based on studies and analyses of human dietary consumption of manganese, which indicated that normal intakes of as high as, and even higher than 10 mg Mn/day (0.14 mg/kg/day) occur and are without adverse consequences. A modifying factor of 3 is to be applied when assessing the potential hazard of exposure to manganese from drinking water or soil. (Application of this factor results in a value of 0.047 mg/kg/day.)

The National Toxicology Program (NTP 2001) does not list manganese as a substance known or reasonably anticipated to be a human carcinogen and IARC has not published a monograph on the potential carcinogenicity of manganese. EPA (IRIS 2001) has classified manganese in Group D—not classifiable as to human carcinogenicity, based on a lack of human data and inadequate animal data.

## B.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

A TTD for chronic oral exposure to manganese was derived for the endpoint affected by manganese and one or more of the other chemicals in the lead, manganese, zinc, and copper mixture that is the subject of this Interaction Profile, using the methods described in ATSDR (2001a, 2001b). The relevant endpoints for this mixture include neurological and hematological. Manganese is neurotoxic, but the available data for oral exposure were considered inadequate for MRL derivation by ATSDR (2000) because no clear threshold level for neurological effects could be determined from the acute- and intermediate-duration data, and because no firm conclusions were considered possible regarding a critical effect level of chronic intake versus essential dietary levels of chronic intake of manganese. Therefore, ATSDR (2000) recommended a provisional guidance value for total dietary intake of 0.07 mg Mn/kg/day, based on the upper end of the ESADDI range (5 mg/day, divided by 70 kg, the weight of an average adult), to be used in ATSDR human health assessments. This value is suitable as a TTD for neurological effects.

### Summary (TTD for Manganese)

TTD_NEURO_ = 0.07 mg/kg/day

## B.6 References

ATSDR. 2000. Toxicological profile for manganese. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001b. Guidance manual for the preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
IRIS. 2001. Integrated Risk Information System. U.S. Environmental Protection Agency. Http://www.epa.gov/iris/subst/index.htm. April 17, 2001.
NRC. 1989. Recommended dietary allowances. 10^th^ ed. Washington, DC: National Academy Press. National Research Council. 205–213, 224–235, 284–285.
NTP. 2001. 9^th^ Report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services. National Toxicology Program. Http://ehis.niehs.nih/gov/roc/toc9.html. September 11, 2001.
Roels HA, Ghyselen P, Buchet JP, 1992. Assessment of the permissible exposure level to manganese in workers exposed to manganese dioxide dust. Br J Ind Med 49:25–34. (As cited in ATSDR 2000).1733453