# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ALA: delta-aminolevulinic acid
ALAD: delta-aminolevulinic acid dehydratase
ALAS: delta-aminolevulinic acid synthetase
ATPase: adenosine triphosphatase
ATSDR: Agency for Toxic Substances and Disease Registiy
BINWOE: binary weight-of-evidence
BMD: benchmark dose
BMDL_10_: benchmark dose, increased risk of 10%
CDC: Centers for Disease Control
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
CI: confidence interval
Cu: copper
dL: deciliter
DNA: deoxyribonucleic acid
DT: Division of Toxicology
EDTA: calcium disodium ethylenediamine
EPA: Environmental Protection Agency
ESADDI: estimated safe and adequate daily dietary intake
FDA: Food and Drag Administration
FEP: free erythrocyte protoporphyrin
FQPA: Food Quality Protection Act
GABA: gamma-aminobutyric acid
GOT: glutamic-oxaloacetic transaminase
HDL: high density lipoprotein
IARC: International Agency for Research on Cancer
IEUBK: Integrated Exposure Uptake Biokinetic
i.p.: intraperitoneal
IRIS: Integrated Risk Information System
Kg: kilogram
L: liter
LOAEL: lowest-observed-adverse-effect level
mg: milligram
Mn: manganese
MRL: Minimal Risk Level
NIH: National Institutes of Health
NMDA: N-methyl-D-aspartate
NOAEL: no-observed-adverse-effect level
NRC: National Research Council
NTP: National Toxicology Program
Pb: lead
PbB: blood lead concentration
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic pharmacodynamic
ppm: parts per million
RDA: Recommended Dietary Allowance
RfC: reference concentration
RfD: reference dose
RNA: ribonucleic acid
SGOT: serum glutamic-oxaloacetic transaminase
TLV: threshold limit value
TTD: target-organ toxicity dose
μg: microgram
UL: tolerable upper intake level
μmole: micromole
U.S.: United States
WOE: weight-of-evidence
Zn: Zinc
ZPP: zinc protoporphyrin
>: greater than
≥: greater than or equal to
=: equal to
≈: approximately equal to
<: less than
≤: less than or equal to