# 5 List of References

*Cited in text

*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 1997. Toxicological profile for cyanide. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
ATSDR. 1999a. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 1999b. Toxicological profile for uranium. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001a. 2001 CERCLA priority list of hazardous substances. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service. http://www.atsdr.cdc.gov/clist.html.
*ATSDR. 2001b. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001c. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001d. Toxicological profile for fluorine, hydrogen fluoride, and fluorides. Draft for public comment. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*Biaglow JE, Durand RE. 1978. The enhanced radiation response of an in vitro tumour model by cyanide released from hydrolysed amygdalin. Int J Radiat Biol Relat Stud Phys Chem Med 33(4):397–401.417038
*Burrows, GE, Way JL. 1979. Cyanide intoxication in sheep: enhancement of efficacy of sodium nitrite, sodium thiosulfate, and cobaltous chloride. Am J Vet Res 40(5):613–7.475106
*Cannon EP, Leung P, Hawkins A, . 1994. Antagonism of cyanide intoxication with murine carrier erythrocytes containing bovine rhodanese and sodium thiosulfate. J Toxicol Environ Health 41(3):267–74.8126749
*Chen KK, Rose CL. 1952. Nitrite and thiosulfate therapy in cyanide poisoning. J Am Med Assoc 149(2):113–119.14917568
ICRP. 1979. Limits for intakes of radionuclides by workers. International Commission of Radiological Protection. ICRP Publication 30. New York: Pergamon Press. 30
ICRP. 1990. 1990 Recommendations of the International Commission on Radiological Protection. International Commission of Radiological Protection. Annals of the ICRP. ICRP Publication No. 60.
ICRP. 1991. 1990 Recommendations of the International Commission on Radiological Protection. International Commission on Radiological Protection. Annals of the ICRP 21(1–3):1–195.
ICRP. 1993. Age-dependent doses to members of the public from intake of radionuclides: Part 2. Ingestion dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 67.
ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4. Inhalation dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 71.
ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides: Part 5 Compilation of ingestion and inhalation dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 72.
*IRIS. 2002. Integrated risk information system (IRIS). U.S. Environmental Protection Agency. http://www.epa.gov/iris/.
*Isom GE, Way GL. 1974. Effect of oxygen on cyanide intoxication. VI. Reactivation of cyanide-inhibited glucose metabolism. J Pharmacol Exper Ther 189(1):235–43.4823293
*Mikaelsen K. 1954. Protective properties of cysteine, sodium hyposulfite, and sodium cyanide against radiation induced chromosome aberrations. Proc Natl Acad Sci USA 40:171–78.16589451
NCRP. 1999. Recommended screening limits for contaminated surface soil and review of factors relevant to site-specific studies. National Council on Radiation Protection and Measurements. NCRP Report No. 129.
NRC. 2001. Annual limits on intake (ALIs) and derived air concentrations (DACs) on radionuclides for occupational exposure. Effluent concentrations; concentrations for release to sewerage. Code of Federal Regulations. Chapter 1, Part 20, Appendix B. http://www.nrc.gov/NRC/CFR/PART020/part020-appb.html. May 23, 2001.
*NTP. 1993. National Toxicology Program Technical Report on toxicity studies of sodium cyanide (CAS No. 143-33-9) administered in drinking water to F344/N rats and B6C3Fl mice, NIH Publication 94-3386. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
*Paitian NA, Markossian KA, Nalbandyan RM. 1985. The effect of nitrite on cytochrome oxidase. Biochem Biophys Res Commun 133(3):1104–11.3002364
*Schubert J. 1991. Radioprotection of lethally irradiated animals: formulation and correlations. Health Phys 61(6):863–69.1659566
*Schubert J, Pan SF, Wald N. 1992. Chromosome aberrations reduced in whole-body irradiated mice by pretreatment with cyanide. Mutat Res 282(2):107–11.1377348
*Szabo AJ, Grimaldi RD, deLellis R. 1973. Triglyceride synthesis by the human placenta. II. The effect of cyanide and fluoride on the incorporation of labeled palmitate into placental triglycerides. Am J Obstet Gynecol 115(2):263–66.4691844
*Tadic V. 1992. The in vivo effects of cyanide and its antidotes on rat brain cytochrome oxidase activity. Toxicology 76(1):59–67.1335620
*Way JL, Leung P, Cannon E, . 1988. The mechanism of cyanide intoxication and its antagonism. Ciba Found Symp 140:232–43.3073059
*Whitford GM, Pashley DH. 1991. Fluoride reabsorption by nonionic diffusion in the distal nephron of the dog. Proc Soc Exp Biol Med 196:178–183.1990408