# SUMMARY

Uranium and fluoride are used in conjunction with nitrate when separating isotopes of uranium via the gaseous diffusion process. This process has been used at several U.S. Department of Energy (DOE) facilities, and continues to be used today. In addition, cyanide has been reported with great frequency as a contaminant at NPL sites. Review of ATSDR’s documents with site-specific information showed that uranium, fluoride, cyanide, and nitrate were reported at one site (Pantax Plant site), while three-component submixtures were reported at eight additional sites: Eastern Michaud Flats, Monticello Mill, Alcoa/Lavaca Bay, Depue/New Jersey Zinc/Mobil Chemical, Hipps Road Landfill, Riverbank Army Ammunition Plant, Savanna Army Depot, and Santa Susana Field Laboratory. The purposes of this profile are to: (1) evaluate data (if available) on health hazards, and their dose-response relationships, from oral exposure to this four-component mixture; (2) evaluate data on the joint toxic actions of components of this mixture; and (3) make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

Evaluation of the available environmental fate data for the components of the mixture suggests that in the event of exposure, the primary route of exposure of nearby populations to mixtures of these chemicals in soil is likely to be oral, resulting from contamination of soil and/or groundwater. ATSDR toxicological profiles are available for cyanide, uranium, and fluoride (ATSDR 1997, 1999b, 2001d, respectively); these documents are the primary sources of information presented in the Appendices concerning the toxicokinetics, health effects, mechanisms of action, and health guidelines for these chemicals. Neither a toxicological profile nor Minimal Risk Levels (MRLs) are available for nitrate; however, U.S. EPA (IRIS 2002) has derived an oral reference dose (RfD) for nitrate.

No studies were located that examined health effects in humans or animals exposed to mixtures exclusively containing uranium, fluoride, cyanide, and nitrate, and no physiologically-based pharmacokinetic/pharmacodynamic (PBPK/PD) models for this mixture have been developed. A component-based approach (ATSDR 2001b, 2001c) was applied, wherein the potential influence of individual components on the toxicity of other components in the mixture is evaluated. For the purposes of component analysis, the toxicity from uranium radiation was considered as a separate element from the chemical toxicity of uranium. As joint action data are lacking for the majority of the component pairs, the mechanisms of action for each component pair were also analyzed for evidence of potential joint toxic actions. The weight-of-evidence analysis suggests greater-than-additive joint actions for one component pair (fluoride and cyanide, in both directions), and less-than-additive joint actions for two of the component pairs (cyanide’s effect on the toxicity of uranium radiation and nitrate’s effect on cyanide toxicity).

Component-based approaches that assume endpoint-specific additive joint toxic action are recommended for exposure-based assessments of possible noncancer or cancer health hazards from oral exposure to uranium, fluoride, cyanide, and nitrate, because there are no direct data available to characterize health hazards (and dose-response relationships) from the four-component mixture. The weight-of-evidence analysis indicated that data are inadequate to characterize the modes of joint action of the majority of the components, but the additivity assumption appears to be suitable in the interest of protecting public health.

A target-organ toxicity dose (TTD) modification of the hazard index approach is recommended for conducting exposure-based assessments of noncancer health hazards. Where data are available, TTDs for several toxicity targets have been recommended for each of the components, including TTDs for renal, reproductive, and neurological effects.