# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Dr. Christopher Borgert
  Applied Pharmacology and Toxicology, Inc.
  238 Turkey Creek
  10514 Palmetto Boulevard
  Alachua, FL 32615
  USA
- Dr. Kannan Krishnan
  Department of Occupational and Environmental Health
  University of Montreal
  2375 Cote Ste Catherine, Office 4105
  Montreal, Quebec H3T 1A8
  Canada
- Dr. Richard Leggett
  Biosystems Modeling Group
  Oak Ridge National Laboratory
  P.O. Box 2008, 1060 Commerce Park, MS-6480
  Oak Ridge, TN 37831-6480

All reviewers were selected in conformity with the conditions for peer review specified in CERCLA Section 104(I)(13).

Scientists from ATSDR have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.