# APPENDIX D Background Information for Nitrate

## D.1 Toxicokinetics

Available studies indicate that oral absorption of nitrate is nearly 100% (for reviews, see EPA 1990 and WHO 1978). Witter (1979, cited in EPA 1990) administered oral radioactive nitrate ion to two male volunteers; one received the nitrate 1 hour after a large meal, the other about 10 hours after eating. In the subject who had recently eaten, the radioactivity had a disappearance half-life from the stomach of about 30 minutes, but the radioactivity in the pylorus remained constant, suggesting that the nitrate had moved to the small intestine rather than being absorbed through the stomach. In the second subject, the disappearance half-life was 10 minutes. Studies in animals have also demonstrated that the bulk of an orally-administered nitrate exposure is absorbed through the small intestine, likely through the upper portion of that organ. Absorbed nitrate is distributed throughout the body, but does not appear to accumulate in any organ (EPA 1990).

The major metabolic pathway for nitrate is conversion to nitrite, and then to ammonia. Small amounts of nitrate, perhaps 5–10% of the total exposure, are converted to nitrite by bacteria in the saliva, stomach, and small intestine. This reaction is pH dependent, with no nitrate reduction occurring below pH 4 and above pH 9, and the presence of oxygen inhibits the reduction of nitrite to ammonia. Absorbed nitrite rapidly reacts with hemoglobin in the blood to form methemoglobin, which in adults, is rapidly converted to oxyhemoglobin, then back to hemoglobin. In infants, particularly those under 3 months old, these reducing systems are not fully developed, which may result in a buildup of methemoglobin in the blood. Due to the higher stomach pH typically found in infants, it is believed that they also convert more nitrate to nitrite in the stomach than adults. There are large species differences in the rate of reaction of nitrite with hemoglobin, paralleled by similar differences in the rates of reduction of methemoglobin, making extrapolation of results from animal data to humans problematic. Another potential metabolic pathway, though less prevalent than the reaction with hemoglobin, is the reaction of nitrite with endogenous molecules to form N-nitroso compounds, many of which have toxic effects, including carcinogenicity.

Available data in humans have demonstrated that elimination of ingested nitrate is rapid, with elimination almost exclusively in the urine (EPA 1990; WHO 1978). Animal data support this observation. In both humans and animals, considerably more nitrate is eliminated in the urine than is ingested in a normal diet, implying that there is significant endogenous nitrate formation.

Parks et al. (1981, cited in EPA 1990) reported that following intratracheal instillation of trace amounts of nitrate to BALB/C mice, absorption from the lungs was complete within a 10-minute period. Additional studies of the toxicokinetics of inhaled nitrate are not available; however, the behavior of absorbed nitrate following inhalation exposure is not expected to differ from nitrate absorbed following oral exposure.

## D.2 Health Effects

The most sensitive known effects of exposure to nitrate result from increased levels of methemoglobin arising from the nitrite-hemoglobin reaction. In healthy adults, methemoglobin formation and reduction is continuous, with steady-state methemoglobin levels in healthy adults being 2.5% of the total hemoglobin content or lower (EPA 1990). Due to the large excess capacity of the blood to carry oxygen, levels of methemoglobin up to 10% typically do not cause significant clinical signs. Levels above 10% may result in cyanosis, weakness, rapid pulse, and, at levels exceeding 50%, death. Other reported effects of nitrate in animals include altered thyroid function, amyloidosis of the liver, kidney, spleen, and adrenal glands, and altered lung and liver weights.

Because of greater numbers of nitrate-reducing bacteria in the gastrointestinal tract and diminished methemoglobin-reducing capacity, infants, particularly those 3 months and younger, are particularly susceptible to nitrate/nitrite-induced methemoglobinemia. A study by Bosch et al. (1950) examined 139 cases of methemoglobinemia in young children (90% occurred in children <2 months of age). Examination of the wells used to supply water to the children revealed that none of the wells supplied <10 mg/L nitrate-nitrogen, with all but two of the wells containing >25 mg/L. Walton (1951) presented the results of a survey on morbidity and mortality among infants due to methemoglobinemia. The results of the survey revealed 239 cases of infant methemoglobinemia, 39 of them fatal. Of the 214 cases where quantitative data were available on nitrate levels in water, none occurred in infants consuming water with <10 mg/L nitrate-nitrogen, 5 cases occurred in infants exposed to 11–20 mg/L nitrate-nitrogen, 36 cases in infants exposed to 21–50 mg/L nitrate-nitrogen, and 173 cases in infants exposed to >50 mg/L nitrate-nitrogen. Many other studies have examined the effects of high (>20 mg/L) levels of nitrate in the drinking water of infants, and have found increased methemoglobin levels and signs of clinical methemoglobinemia in exposed infants (for reviews, see EPA 1990 and WHO 1978).

## D.3 Mechanisms of Action

The known toxic effects of nitrate exposure result from the conversion of nitrate to nitrite. The conversion is mainly the result of bacterial oxidation reactions within the gastrointestinal tract. Exposure of hemoglobin to nitrite results in the oxidation of the Fe^2+^ ion in the heme of hemoglobin to Fe^3+^, resulting in the formation of methemoglobin. Methemoglobinemia results in the majority of the symptoms seen following high-dose acute nitrate exposure in humans. Under normal conditions, healthy adults will have <2.5% methemoglobin in the blood. Methemoglobin can be reduced back to hemoglobin by both spontaneous (nicotinamide adenine dinucleotide phosphate [NADH]-dependent) and dormant (NADPH-dependent) methemoglobin reductase enzymes.

Infants are particularly susceptible to methemoglobinemia due to their high gut content of nitrate-reducing bacteria, their lower enzymatic capacity to reduce methemoglobin to hemoglobin, and to the presence of hemoglobin F, which is more susceptible to oxidation by nitrite. The high pH of the infant gastrointestinal system favors the growth of nitrate-reducing bacteria, particularly in the stomach and especially after ingestion of contaminated waters, since the ingested bacteria are likely to flourish in the stomach. The stomach of adults is typically too acidic to allow for significant bacterial growth and the resulting conversion of nitrate to nitrite. Additionally, the enzymes involved in the conversion of methemoglobin to hemoglobin do not fully develop in humans until between 3 and 6 months after birth, resulting in an increased susceptibility to methemoglobinemia.

As mentioned in Section D.1, the reaction rates for the nitrite-hemoglobin reaction vary considerably across species (many animal species lack nitrate-reducing bacteria), as do the rates of the reactions reducing methemoglobin back to functional hemoglobin. Also, since the rates of conversion of nitrate to nitrite by bacteria can vary within individuals, the extent of nitrate toxicity can also vary greatly depending on age and other factors within both humans and animals.

## D.4 Health Guidelines

ATSDR has not published a toxicological profile for nitrates. No MRL values are available.

EPA (IRIS 2002) has derived an oral RfD of 1.6 mg/kg/day for nitrate, based on a NOAEL of 1.6 mg/kg/day for methemoglobinemia in exposed infants (Bosch et al. 1950; Walton 1951). An uncertainty factor of 1 was applied to the NOAEL since the study was performed in a sensitive population of humans (infants age 0–3 months). No RfC for nitrate has been derived, and nitrate has not undergone an evaluation of carcinogenic potential by EPA.

## D.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

ATSDR has not published a toxicological profile for nitrates; no MRLs exist for exposure to nitrate by any route of exposure. As no shared targets of toxicity for nitrate and any of the other components of the mixture exist, no TTDs for nitrate were derived.

## D.6 References

Bosch HM, Rosefield AB, Huston R, . 1950. Methemoglobinemia and Minnesota well supplies. J Am Water Works Assoc 42:161–170.
EPA. 1990. Criteria document for nitrate/nitrite. Office of Drinking Water, U.S. Environmental Protection Agency, Washington, DC.
IRIS. 2002. Integrated Risk Information System (IRIS). U.S. Environmental Protection Agency. http://www.epa.gov/iris.
Parks NJ, Krohn KA, Mathis CA, . 1981. Nitrogen-13-labeled nitraite and nitrate: Distribution and metabolism after intratracheal administration. Science 212:58–61. (As cited in EPA 1990.)7209517
Walton, G. 1951. Survey of literature relating to infant methemoglobinemia due to nitrate-contaminated water. Am J Public Health 41:986–996.
WHO. 1978. World Health Organization. Environmental Health Criteria 5: Nitrates, nitrites and N-nitroso compounds. Geneva: World Health Organization.
Witter JP, Gatley SJ, Balish E. 1979. Distribution of nitrogen-13 from labeled nitrate (^13^NO_3_^−^) in humans and rats. Science 204:411–413. (As cited in EPA 1990.)441728