# APPENDIX C Background Information for Cyanide

## C.1 Toxicokinetics

Cyanide is rapidly absorbed (within seconds) following inhalation exposure. Humans retained 58% of hydrogen cyanide in the lungs after inhaling the gas through normal breathing (Landahl and Herrmann 1950). During inhalation exposure of dogs to an unknown concentration of hydrogen cyanide (Gettler and Baine 1938), one dog reportedly absorbed 16.0 mg (1.55 mg/kg); the other dog absorbed 10.1 mg (1.11 mg/kg). These doses were fatal to the dogs in 15 and 10 minutes, respectively. More recent quantitative data were not available. Following oral exposure, cyanide is rapidly absorbed, as evidenced by the death of an exposed dog as early as 8 minutes following exposure (Gettler and Baine 1938); the absorption of cyanide varied from 17 to 74% in the three exposed dogs. A more recent study in rats (Farooqui and Ahmed 1982) indicated that at least 53% of a single oral dose of cyanide in rats was absorbed within 24 hours of exposure. Evidence for dermal absorption of cyanide comes from studies in animals (ATSDR 1997) wherein systemic toxicity was observed following dermal contact with cyanide compounds; however, quantitative data on the dermal absorption of cyanide are not available.

Following absorption, cyanide is rapidly distributed by the blood throughout the body. After inhalation exposure in humans, tissue cyanide levels, expressed per gram of wet tissue, were highest in the lung, followed by the heart, blood, kidney, brain, and liver (ATSDR 1997). Similar distribution patterns were seen in animals after cyanide inhalation. In humans who had died of oral cyanide overdose, cyanide levels were generally greatest in the stomach contents, with significant levels reported in the spleen, lungs, blood, liver, brain, and kidney (ATSDR 1997). Following oral exposure in animals, a similar pattern was seen, with the greatest levels in the stomach contents, with significant levels in the liver, lung, blood, and kidney (ATSDR 1997). Cyanide in the blood was found mainly (95%) in the hemolysate, with 70% of the total cyanide found in the heme-containing fraction (Farooqui and Ahmed 1982). Cyanide has not been reported to accumulate in the body.

Reports of ingestion of cyanides by humans and reports of occupational exposure indicate that cyanide is transformed into thiocyanate. A plasma half-life of 20 minutes to 1 hour has been estimated for cyanides in humans after nonlethal exposures (Hartung 1982). Animal data indicate that the primary pathway of cyanide metabolism involves transformation to thiocyanate by either rhodanese or 3-mercaptopyruvate sulfur transferase, accounting for 60–80% of the administered dose (ATSDR 1997). Species and tissue distribution of rhodanese is highly variable, with dogs possessing the lowest levels of all species examined (Himwich and Saunders 1948). Minor pathways of cyanide metabolism include (1) conversion to 2-aminothiazoline-4-carboxylic acid; (2) incorporation into a 1-carbon metabolic pool; or (3) combining with hydroxocobalamin to form cyanocobalamin (vitamin B_12_).

Cyanide metabolites are normally excreted in urine with small amounts eliminated through the lungs. Urinary excretion of thiocyanate was monitored in a man after ingestion of ~3–5 grams of potassium cyanide (15–25 mg CN^−^/kg) (ATSDR 1997). The results indicated that the patient excreted 237 mg of thiocyanate over a 72-hour period. This quantity was substantially more than the normal average amount of thiocyanate in urine, which varies between 0.85 and 14 mg/24 hours. Thirty-one children who had consumed flour made from insufficiently processed cassava, which therefore had significant concentrations of cyanide, had mean urinary thiocyanate levels of 757 :mol/L, compared with 50 :mol/L in those children who had consumed sufficiently processed cassava. When rats were given 2 mg CN^−^/kg of radiolabeled potassium cyanide, urinary excretion of radioactivity reached 47% of the dose within 24 hours following administration. When [^14^C] sodium cyanide was injected subcutaneously into rats at a level of 8.3 :mol, no difference in radioactivity eliminated was observed between the group pretreated for 6 weeks with a diet containing 0.7 mg CN^−^/kg as potassium cyanide and their matching controls. Most of the radioactivity was detected in the urine (89% by 24 hours). Thiocyanate was the major metabolite. About 4% of the radioactivity was expired, mostly as carbon dioxide.

## C.2 Health Effects

Studies of the acute effects of cyanide inhalation have generally been limited to the examination of serious and lethal effects. Acute inhalation exposure to high levels of cyanide, regardless of the form, leads quickly to death that is preceded by dyspnea, convulsions, and central nervous system depression (ATSDR 1997). A human 10-minute LC_50_ of 524 ppm for cyanide inhalation has been estimated (ATSDR 1997), while Singh et al. (1989) reported that a man exposed to 192 ppm died within 3 days of exposure. Rat LC_50_ values of 483 ppm cyanide for a 5-minute exposure and 137 ppm cyanide for a 60-minute exposure have been reported (ATSDR 1997). Mouse LC_50_ levels are similar to those in rats, with LC_50_ values of 310 ppm cyanide for a 5-minute exposure and 159 ppm cyanide for a 30-minute exposure (ATSDR 1997). Other acute effects of cyanide inhalation include peripheral vision loss in a male human exposed for 13 minutes to 434 ppm cyanide as hydrogen cyanide and dyspnea, bradycardia, arrhythmia, and EEG alterations in monkeys exposed for 30 minutes to 96 ppm cyanide as hydrogen cyanide.

Data on the effects of subchronic or chronic inhalation exposure to cyanide in humans and animals are limited. In an early study, four dogs were exposed to 43 ppm cyanide as hydrogen cyanide for 30 minutes every other day for 28 days. One dog of four died, while other affected endpoints included the respiratory (dyspnea), gastrointestinal (vomiting, tenesmus, and diarrhea), and neurological (tremors, ataxia, stiffness, cellular atrophy) effects. A later study reported increased creatine phosphokinase activity in rats following five 12.5-minute exposures, at 4-day intervals, to 192 ppm cyanide as hydrogen cyanide (ATSDR 1997).

Two chronic studies of humans occupationally exposed to cyanide are reported in ATSDR (1997). El Ghawabi et al. (1975) described a cohort of workers chronically exposed (5–15 years) to 6.4–10.4 ppm of an unspecified cyanide form evolved from sodium cyanide and copper cyanide during electroplating. Reported symptoms included dyspnea, lacrimation, precordial pain, increased hemoglobin and lymphocytes, and vomiting, as well as significant neurological effects, including confusion, hallucination, headache, weakness, and dizziness. A later study (Blanc et al. 1985) described health effects in workers exposed to 15 ppm hydrogen cyanide (14 ppm cyanide) in a silver-reclaiming facility. Symptoms were similar to those reported by El Ghawabi et al. (1975), and included dyspnea, palpitations, chest pain, nausea, altered thyroid hormone levels, rash, decreased body weight, and neurologic effects, including persistent headache, dizziness, and paresthesia. Both of these studies, however, are limited by their inability to control for co-exposure to other compounds.

Case reports of acute oral exposures to cyanide in humans have identified a number of health effects. Stertorous, deep, and rapid breathing was reported in a man who ingested ~15 mg CN^−^ /kg as potassium cyanide in a suicide attempt (Liebowitz and Schwartz 1948), while shortness of breath and dyspnea were observed in two reports of suicide attempts; one man ingested 7.6 mg CN^−^/kg (Goodhart 1994) and the other man ingested 0.57 mg CN^−^/kg (Saincher et al. 1994), both as potassium cyanide. Acute neurologic effects vary with the amount of cyanide consumed, ranging from headache at low doses, to tremor and coma at higher doses (ATSDR 1997). There is evidence that acute oral exposures to cyanide can lead to the development of Parkinsonism (ATSDR 1997). Other reported effects of acute oral cyanide exposure in humans include shallow pulse, albuminuria, increased serum creatinine and serum creatinine kinase, and metabolic acidosis (ATSDR 1997). Hamsters exposed from gestational days 3–14 showed no effects on the number of implantations or resorptions at concentrations up to 10.4 mg CN/kg/day as cassava, but 1 mg CN/kg/day as cassava resulted in significantly decreased fetal weight and delayed bone ossification (Frakes et al. 1986).

Studies of humans orally exposed to cyanide for intermediate duration are lacking. The intermediate-duration oral MRL for cyanide is based on a 13-week drinking water study performed by NTP (1993) which defined a NOAEL of 4.5 mg/kg/day and a LOAEL of 12.5 mg/kg/day for decreased weights of male reproductive organs and altered spermatogenesis in male F344 rats. The study did not report effects on other organ systems, including neurological effects, in rats at doses up to 12.5 mg/kg/day or in mice at doses up to 24.3 mg/kg/day in males and 28.8 mg/kg/day in females. In contrast, Gerhart (1986, 1987a, 1987b) reported altered posture and hypoactivity in Sprague-Dawley rats exposed by gavage for 90 days to 0.8 mg CN/kg/day as KAg(CN)_2_ or 0.14 mg CN/kg/day as CuCN, with labored respiration seen at 0.8 mg CN/kg/day as KAg(CN)_2_ or 4.35 mg CH/kg/day as CuCN. Gerhart (1986, 1987a, 1987b) also reported increased testicular weight at 2.6 mg CN/kg/day as KAg(CN)_2_ or 14.5 mg CN/kg/day as CuCN. A 14-week study in male dogs identified LOAELs of 1.04 mg CN/kg/day, regardless of whether the food contained NaCN or cassava, for cardiac swelling and hemorrhage, proximal tubule damage, kidney congestion and vacuolation, adrenal cortex swelling and fibrosis, and destruction of germ cells in the seminiferous tubules (Kamalu 1993). However, as dogs have very low levels of rhodanese relative to humans, and thus a higher sensitivity to the effects of cyanide, the implication of these studies relative to risks in humans is uncertain.

Data on the effects of chronic oral exposure to cyanide, including studies of carcinogenicity, in humans and animals are lacking.

## C.3 Mechanisms of Action

Cyanide (as hydrogen cyanide), originating in vivo by dissociation of potassium cyanide, sodium cyanide, and other cyanogenic compounds or arising from catabolism of cyanogenic glycosides, exerts its acute toxic effects by complexing with the ferric iron atom in metalloenzymes, resulting in histotoxic anoxia through inhibition of cytochrome c oxidase (ATSDR 1997), metalloenzymes that function as the terminal oxidase of the inner mitochondrial membrane respiratory chain. A two-step process has been proposed: cyanide as hydrogen cyanide first penetrates a protein crevice of cytochrome c oxidase and binds to the protein. Hydrogen cyanide then binds to the trivalent iron ion of the enzyme, forming a relatively stable (but reversible) coordination complex. One mole of hydrogen cyanide is bound to one mole of cytochrome c oxidase. As a result, the enzyme becomes unable to catalyze the reactions in which electrons would be transferred from reduced cytochrome to oxygen. Cellular oxygen utilization is thus impaired, with resultant reduction in or cessation of aerobic metabolism (ATSDR 1997). Glucose catabolism then shifts from the aerobic pathway to anaerobic metabolism including the pentose phosphate pathway, resulting in increased blood glucose, pyruvic acid, lactic acid, and nicotinamide adenine dinucleotide phosphate (NADPH) levels, and a decrease in the adenosine triphosphate/adenosine diphosphate (ATP/ADP) ratio.

The inhibition of oxygen use by cells (termed histoxic hypoxia) causes oxygen tensions to rise in peripheral tissues. This results in a decrease in the unloading gradient for oxyhemoglobin; thus, oxyhemoglobin is carried in the venous blood. Inhibition of oxygen utilization is thought to occur rapidly after cyanide exposure (ATSDR 1997). Tadic (1992) determined that inhibition of cytochrome c oxidase activity in rat brains was most pronounced between 15 and 20 minutes after administration of sodium cyanide (12 mg/kg or 1.3xLD_50_). In addition to binding to cytochrome c oxidase, cyanide also binds to catalase, peroxidase, methemoglobin, hydroxocobalamin, phosphatase, tyrosinase, ascorbic acid oxidase, xanthine oxidase, and succinic dehydrogenase.

The central nervous system is the primary target for acute cyanide toxicity in humans and animals. Acute inhalation of high concentrations of cyanide provokes a brief central nervous system stimulation followed by depression, convulsions, coma, and death in humans and in animals (ATSDR 1997). The effects are probably due to rapid biochemical changes in the brain, such as changes in ion flux, neurotransmitter release, and possibly peroxide formation (ATSDR 1997).

Cyanide poisoning likely involves mechanisms in addition to inhibition of cytochrome c oxidase activity. Cyanide is a strong nucleophile with multiple effects including release of secondary neurotransmitters, release of catecholamines from adrenal glands and adrenergic nerves, and inhibition of antioxidant enzymes in the brain. However, the extremely low concentration of cyanide required to inhibit the oxidase, the rapid interaction of hydrogen cyanide with the enzyme and the key role of cytochrome c oxidase in aerobic metabolism all combine to make cyanide inhibition of the terminal step of electron transport (ATSDR 1997) the key molecular target in cyanide poisoning.

## C.4 Health Guidelines

ATSDR (1997) did not derive inhalation MRLs for cyanide for any exposure duration, because available studies were not adequate. Many of the animal and human studies used lethality, or serious effects, as the endpoint. Two available epidemiology studies were not used because of inadequate exposure characterization or co-exposure to other chemicals.

ATSDR (1997) did not derive an acute oral MRLs for cyanide because most of the available studies reported lethality as the endpoint, and because of a general lack of information as to acute systemic effects of cyanide.

ATSDR (1997) derived an intermediate oral MRL of 0.05 mg/kg/day for cyanide based on a NOAEL of 4.5 mg/kg/day for reproductive effects, such as decreased epididymal weight, decreased testis weight, and alterations in spermatozoa in male rats (NTP 1993). The MRL was derived by applying an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for intrahuman variability) to the NOAEL. The rats were exposed for 13 weeks to sodium cyanide in the drinking water.

ATSDR (1997) has not derived a chronic oral MRL for cyanide, due to limitations of exposure analysis in the available human data and a lack of reported effects in the one reported chronic animal study.

EPA oral RfDs have been established for cyanide and its compounds. These RfDs range from 2×10^−1^ mg/kg/day for potassium cyanide to 5×10^−3^ mg/kg/day for copper cyanide (IRIS 2002). The RfDs for potassium silver cyanide and potassium cyanide were based on weight loss and thyroid effects in several rat studies (Howard and Hanzel 1955; Philbrick et al. 1979), while the RfD for copper cyanide was based on decreased body and organ weights and liver and kidney effects in a intermediate-duration rat study (Gerhart 1986). An EPA RfC exists only for hydrogen cyanide; this RfC is 3×10^−3^ mg/m^3^. The RfC was based on central nervous system and thyroid effects in a human occupational study (El Ghawabi et al. 1975).

The EPA has determined that cyanide is not classifiable as to its human carcinogenicity (Group D) (IRIS 2002). No cancer classifications exist for the NTP, Integrated Risk Information System (IRIS), or the International Agency for Research on Cancer (IARC) (no available data).

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to cyanide were derived for endpoints affected by one or more of the other chemicals in the uranium, fluoride, cyanide, and nitrate mixture that is the subject of this Interaction Profile. The relevant endpoints for this mixture include renal, neurological, and reproductive (testicular) effects. Where data are available, chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001c, Section 2.3.2). The derivations are based on data presented in ATSDR (1997).

### Reproductive Effects

ATSDR (1997) derived an intermediate oral MRL of 0.05 mg/kg/day for cyanide based on a NOAEL of 4.5 mg/kg/day for reproductive effects, such as decreased epididymal weight, decreased testis weight, and alterations in spermatozoa in male rats (NTP 1993). The MRL was derived by applying an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for intrahuman variability) to the NOAEL. The rats were exposed for 13 weeks to sodium cyanide in the drinking water.

### Neurological Effects

While a number of human and animal studies have reported neurologic effects from the ingestion of cyanide-containing compounds, none has done so in such a way as to allow for a definitive dose-response analysis of the effect of cyanide on neurological endpoints. For example, Gerhart (1987a, 1987b) examined the effects of copper cyanide and potassium silver cyanide in rats, but was not able to clearly delineate the effects of cyanide from the effects of the metals. Similarly, a number of studies in humans who consumed cassava, which contains considerable levels of cyanide, are complicated by the presence of scopoletin, which may have contributed to the neurological effects seen. As such, none of the available studies are suitable for derivation of a TTD for neurologic effects of cyanide. The MRL of 0.05 mg/kg/day will be adopted as the TTD_NEURO_ for cyanide.

### Renal Effects

Available studies in humans and animals have suggested that renal effects may result from prolonged exposure to cyanide, though reliable quantitative data are limited. The study of Gerhart (1987b), while having the limitation of co-exposure to silver, identified a NOAEL of 2.6 mg/kg/day and a LOAEL of 7.8 mg/kg/day for increased blood urea nitrogen. Studies in dogs have identified lower LOAEL values, but dogs are a poor model for cyanide toxicity in humans due to a lack of rhodanese enzyme levels. Application of an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for intrahuman variability) would yield a TTD_RENAL_ of 3×10^−2^ mg/kg/day. However, as this would fall below the MRL, the MRL of 0.05 mg/kg/day will be adopted as the TTD_RENAL_ for cyanide.

### Summary (TTDs for Cyanide)

MRL_REPRO_ = 0.05 mg/kg/day

TTD_NEURO_ = 0.05 mg/kg/day

TTD_RENAL_ = 0.05 mg/kg/day

## C.6 References

ATSDR. 1997. Toxicological profile for cyanide. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001c. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Blanc P, Hogan M, Mallin K, . 1985. Cyanide intoxication among silver-reclaiming workers. J Am Med Assoc 253:367–371. (As cited in ATSDR 1997.)
El Ghawabi SH, Gaafar MA, El-Saharti AA, . 1975. Chronic cyanide exposure: A clinical, radioisotope, and laboratory study. Br J Ind Med 32:215–219.1156569
Farooqui MYH, Ahmed AE. 1982. Molecular interaction of acrylonitrile and potassium cyanide with rat blood. Chem Biol Interact 38:145–159. (As cited in ATSDR 1997.)7055848
Frakes RA, Sharma RP, Willhite CC, . 1986. Effect of cyanogenic glycosides and protein content in cassava diets on hamster prenatal development. Fundam Appl Toxicol 7:191–198. (As cited in ATSDR 1997.)3758536
Gerhart JM. 1986. Ninety-day oral toxicity study of copper cyanide (CuCN) in Sprague-Dawley Rats. Prepared for The Dynamac Corporation, Rockville, MD by IIT Research Institute, Chicago, IL. IITRI Project No. L06183, Study No. 3. (As cited in ATSDR 1997.)
Gerhart JM. 1987a. Ninety-day oral toxicity study of copper silver cyanide [KAg(CN)_2_] in Sprague-Dawley rats. Prepared for The Dynamac Corporation, Rockville, MD by IIT Research Institute, Chicago, IL. IITRI Project No. L06183, Study No. 4. (As cited in ATSDR 1997.)
Gerhart JM. 1987b. Ninety-day oral toxicity study of potassium silver cyanide [KAg(CN)2] in Sprague-Dawley rats. Prepared for The Dynamac Corporation, Rockville, MD by IIT Research Institute, Chicago, IL. IITRI Project No. LO61 83, Study No. 4. (As cited in ATSDR 1997.)
Gettler AO, Baine JO. 1938. The toxicology of cyanide. Am J Med Sci 195:182–198. (As cited in ATSDR 1997.)
Goodhart GL. 1994. Patient treated with antidote kit and hyperbaric oxygen survives cyanide poisoning. South Med J 87(8):814–816. (As cited in ATSDR 1997.)8052890
Hartung R. 1982. Cyanides and nitriles. In: Clayton GD, Clayton FE, eds. Patty’s industrial hygiene and toxicology. Vol IIC 3rd edition. New York, NY: John Wiley and Sons, 4845–4900. (As cited in ATSDR 1997.)
Himwich WA, Saunders JP. 1948. Enzymatic conversion of cyanide to thiocyanate. Am J Physiol 153:348–354. (As cited in ATSDR 1997.)18872649
Howard JW, Hanzal RF. 1955. Chronic toxicity for rats of food treated with hydrogen cyanide. Agric Food Chem 3:325–329.
IRIS. 2002. Integrated risk information system (IRIS). U.S. Environmental Protection Agency. www.epa.gov/iris/.
Kamalu BP. 1993. Pathological changes in growing dogs fed on a balanced cassava (Manihot esculenta Crantz) diet. Br J Nutr 69(3):921–934. (As cited in ATSDR 1997.)8329365
Landahl HD, Herrmann RG. 1950. Retention of vapors and gases in the human nose and lung. Arch Ind Hyg Occup Med 1:36–45. (As cited in ATSDR 1997.)15419854
Liebowitz D, Schwartz H. 1948. Cyanide poisoning: Report of a case with recovery. Am J Clin Pathol 18:965–970. (As cited in ATSDR 1997.)18105520
NTP. 1993. National Toxicology Program Technical Report on toxicity studies of sodium cyanide (CAS No. 143-33-9) administered in drinking water to F344/N rats and B6C3Fl mice, NIH Publication 94-3386. U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health.
Philbrick DJ, Hopkins JB, Hill DC, . 1979. Effects of prolonged cyanide and thiocyanate feeding in rats. J Toxicol Environ Health 5:579–592.490674
Saincher A, Swirsky N, Tenenbein M. 1994. Cyanide overdose: Survival with fatal blood concentration without antidotal therapy. J Emerg Med 12(4):555–557. (As cited in ATSDR 1997.)7963405
Singh BM, Coles N, Lewis P, . 1989. The metabolic effects of fatal cyanide poisoning. Postgrad Med J 65:923–925.2616434
Tadic V. 1992. The in vivo effects of cyanide and its antidotes on rat brain cytochrome oxidase activity. Toxicology 76(1):9–67.