# APPENDIX B Background Information for Fluoride

## B.1 Toxicokinetics

Studies on the rate and extent of fluorine absorption are not available, but evidence suggests that fluorine is too reactive to be absorbed unchanged, and instead is absorbed as fluoride. A study in rats suggests that hydrogen fluoride is absorbed primarily by the upper respiratory tract, and that removal of hydrogen fluoride from inhaled air by the upper respiratory tract approaches 100% for exposures that range from 30 to 176 mg fluoride/m^3^ (Morris and Smith 1982). The studies of Collings et al. (1951) and Rye (1961) have demonstrated the absorption of fluoride from fluoride-containing dusts, but did not quantify the rate or extent of the absorption.

Ingested dietary fluoride is readily absorbed from the gastrointestinal tract as the undissociated hydrogen fluoride molecule by passive absorption (Whitford and Pashley 1984). Since the neutral undissociated molecule can penetrate cell membranes and be absorbed much better than the fluoride ion, decreasing the stomach pH increases absorption. The absorption of soluble fluoride in humans is rapid and extensive (~97%) (ATSDR 2001d) with maximum plasma fluoride concentrations attained as early as within 30 minutes following exposure (Ekstrand et al. 1977). However, additional factors can affect absorption. For example, the absorption of fluoride as calcium fluoride is increased when the material is given with meals (Trautner and Einwag 1987).

Following absorption, distribution of fluoride to the blood is rapid. Immediately following 40 minutes of intermittent inhalation exposure, plasma fluoride concentrations correlated closely (correlation coefficient=0.98; p<0.01) with the concentration of hydrogen fluoride in the air passed through the surgically isolated upper respiratory tract. Plasma levels were not measured at time points <40 minutes. Reports of skeletal fluorosis and elevated bone fluoride levels after occupational exposure to hydrogen fluoride and fluoride dusts indicate that fluoride is distributed to bone, mainly in regions undergoing active ossification or calcification, and accumulates there after inhalation exposure (ATSDR 2001d).

Long-term retention and accumulation of fluoride are primarily confined to calcified tissue in humans, though soft tissue concentrations of fluoride do rise transiently following ingestion of fluoride (ATSDR 2001d). Teeth and bone readily take up fluoride following oral exposure (ATSDR 2001d). While the rate of fluoride uptake in human teeth may decrease with age, it is apparent that the total fluoride content of teeth and bone increases throughout life, and that the amount deposited is dependent on the exposure concentration. With the exception of the aorta and kidney, there is no evidence of accumulation or retention of fluoride in soft tissues in humans (ATSDR 2001d). Upon cessation of exposure, fluoride levels in bone are expected to decrease slowly; however, the time period over which this would occur in humans is not known.

Fluoride is believed to replace the hydroxyl ion and possibly the bicarbonate ion associated with hydroxyapatite—a mineral phase during formation of bone (ATSDR 2001d). The resultant material is hydroxyfluorapatite. Once absorbed, a portion of the fluoride is deposited in the skeleton, and the remainder is excreted in the urine, feces, sweat, and saliva within 24 hours (ATSDR 2001d). Thus, skeletal sequestration and renal excretion are the two major means by which the body prevents circulation of toxic amounts of fluoride ion. Fluoride in the skeleton is removed approximately at the rate of bone remodeling. Urinary excretion is markedly decreased in the presence of decreased renal function (ATSDR 2001d).

The fluoride ion carried in human blood serum exists in two forms, namely as an inorganic ion F^−^ and in combination with an organic molecule (Halton et al. 1984). The toxicological significance, if any, of the latter form is unknown. A portion of the circulating inorganic fluoride acts as an enzyme inhibitor because it forms metal-fluoride-phosphate complexes that interfere with the activity of those enzymes requiring a metal ion cofactor. In addition, fluoride may interact directly with the enzyme or the substrate. It is a general inhibitor of the energy production system of the cell, and of glycolysis in particular (ATSDR 2001d). Although much is known about enzyme inhibition by fluoride, the human health significance remains to be determined. The studies on enzymatic inhibition by fluoride were in vitro studies and used fluoride concentrations that were significantly higher than concentrations that would be normally found in human tissues.

No data were located regarding excretion of fluoride following human inhalation exposure to fluorine. Urinary fluoride levels were increased in dogs and rabbits exposed to levels as low as 0.8 mg/m^3^ for 5–6 hours/day, 6 days/week for 35 days (Stokinger 1949). No quantitative data were reported at this level, but urinary fluoride levels in rabbits exposed to 3 mg/m^3^ were 1.5 times normal. Studies in humans indicate that fluoride absorbed from inhaled hydrogen fluoride over an 8-hour work shift is excreted even during exposure, with urinary excretion peaking approximately 2–4 hours after cessation of exposure (about 10 hours following beginning of exposure) (Collings et al. 1951; Rye 1961).

The principal route of elimination of ingested fluoride is via the urine as demonstrated in a variety of species. In general, urine accounts for about 50–70% of the fluoride intake and feces accounts for 5–10%. Estimates of total elimination range from about 50% (Spencer et al. 1970) to about 100% (McClure et al. 1945). These varying estimates lead to widely varying estimates of the amount of fluoride that is stored in the body. There is a striking linear relationship between the concentration of fluoride in drinking water and in the urine of humans exposed continuously to fluoride. However, plasma fluoride levels are reflected better by the urinary fluoride excretion rate than by the concentration of fluoride in the urine (Ekstrand and Ehrnebo 1983). Large amounts of fluoride were excreted for prolonged periods by persons who lived for many years in areas with high fluoride water levels and who subsequently moved to areas with low fluoride levels, which indicated the excretion of fluoride that was mobilized from bone (Likins et al. 1962).

## B.2 Health Effects

The primary effects of fluorides following acute inhalation exposure consist of irritation of the respiratory tract, with hematologic, renal, and hepatic effects seen in animal studies. Humans exposed to fluorine, which is thought to be rapidly converted to fluoride upon contact with tissues, have reported nasal irritation at exposures as low as 50 parts per million (ppm) for 3 minutes (Keplinger and Suissa 1968). Animal studies have established 60-minute 50% lethal concentration (LC_50_) values ranging from 150 to 185 ppm for fluorine and from 325 to 1,610 ppm for hydrogen fluoride (ATSDR 2001d). Effects following subchronic inhalation to fluorine and hydrogen fluoride are similar to the acute effects, with nasal irritation being the most sensitive effect reported in humans, and respiratory tract irritation, hemorrhage, and edema being the most sensitive effects seen in animal studies (ATSDR 2001d). No studies of the health effects of chronic inhalation exposure to fluoride in humans or animals were identified.

Eichler et al. (1982) reported that a 3-year-old boy who had consumed a single dose of 16 mg fluoride/kg died 7 hours following ingestion. Upon autopsy, hemorrhagic edema of the lungs, hemorrhagic gastritis, and massive cerebral edema were observed. The hemorrhagic edema observed in the lungs was probably due to aspiration of the gastric contents. Cloudy swelling was observed in the cells of the liver, heart, and kidney. In rats, LD_50_ values for sodium fluoride administered by oral gavage range from 31 to 101 mg fluoride/kg (ATSDR 2001d). These LD_50_ values for rats may vary with strain, weight, and gender. An LD_50_ of 44.3 mg fluoride/kg was reported for mice (Lim et al. 1978). No reproductive effects were seen in mice exposed for 5 days to 32 mg fluoride/kg/day, nor were developmental effects reported in rats exposed to 12.26 mg fluoride/kg/day on gestational days 6–15 or in mice exposed to 13.21 mg fluoride/kg/day (ATSDR 2001d).

Data are not available on the effects of intermediate-duration exposure to fluoride in humans. Intermediate-duration exposure of animals to fluoride has resulted in effects on a number of organ systems, including bone, testes, kidney, neurobehavioral effects, and developmental effects. Effects on the bone are commonly reported, including decreased bone growth, alterations in tooth enamel, delayed bone healing, and increased bone formation rate. A number of studies in rats, mice, and guinea pigs have reported testicular effects, including reduced fertility, decreased sperm counts, and histologic alterations of the seminiferous tubules and Leydig cells. Two studies in rats have demonstrated alterations in spontaneous behavior and decreased spontaneous activity in rats exposed for 6 weeks or 60 days, while two studies in mice have demonstrated renal effects of ingested fluoride. A study in rats reported that exposure of dams to 11.4 mg fluoride/kg/day resulted in an increased number of fetuses per litter with skeletal variations—no other developmental effects of fluoride were identified (ATSDR 2001d).

An extensive database on the effects of oral exposure to fluoride in humans exists, identifying effects on bone as the most sensitive effect of chronic exposure (ATSDR 2001d). Numerous studies have examined the possible relationship between chronic exposure to fluoride in drinking water and the risk of bone fractures. Many of these studies examined communities with high level of fluoride in the water or fluoridated water (ATSDR 2001d); a few prospective or retrospective studies have also examined this possible association. These studies have found conflicting results, with studies finding a lower or higher incidence of hip fractures or no differences in hip fracture between humans exposed to fluoride in drinking water. The chronic oral MRL is based on a LOAEL of 0.56 mg fluoride/kg/day for increased fracture rates in osteoporotic postmenopausal women.

Fluoride results in thickened bones and exostoses (skeletal fluorosis) when ingested in large doses for an extended period of time (ATSDR 2001d). Signs of skeletal fluorosis range from increased bone density to severe deformity, known as crippling skeletal fluorosis. Crippling fluorosis is characterized by complete rigidity of the spine, often accompanied by kyphosis (humpback) or lordosis (arched back). Reported cases are found almost exclusively in developing countries, particularly India, and are associated with malnutrition. The incidence of early skeletal fluorosis in the United States is unknown, since it appears that the early signs can only be identified radiologically. Fluoride may also have effects on the kidney, with a case report demonstrating that exposure to high levels of fluoride resulted in renal insufficiency and interstitial nephritis (ATSDR 2001d).

While animal studies, particularly in minks, have confirmed the toxicity of fluoride in bone, chronic oral studies in animals have also identified effects of fluoride in organs other than bone (ATSDR 2001d). Rabbits exposed to 5 mg fluoride/kg/day as sodium fluoride showed a roughened duodenal mucosa, while exposure of rabbits to 4.5 mg fluoride/kg/day as sodium fluoride resulted in serious testicular effects, with structural damage to the developing spermatids and a complete cessation of spermatogenesis, as well as decreased levels of total primary and secondary antibody titers, suggesting an impaired immune response.

Numerous epidemiological studies have examined the issue of a connection between fluoridated drinking water and cancer. The weight of evidence indicates that no such connection exists. However, all of the investigations were ecologic studies, and the sensitivity limit of even the most sensitive analysis in these studies appears to be a 10–20% increase. Since any carcinogenic effect of fluoride at the levels found in water supplies would probably be below this level of sensitivity, a National Toxicology Program (NTP) cancer bioassay was conducted to assess the effect of fluoride in the drinking water on cancer incidence in animals (Bucher et al. 1991; NTP 1990). The NTP study found equivocal evidence of a fluoride-related increase in osteosarcomas in male rats, and no evidence of any fluoride-related neoplasm in female rats or male or female mice. A lifetime oral study sponsored by Proctor and Gamble (Maurer et al. 1990) found no evidence of fluoride carcinogenicity in either male or female rats exposed in the feed. Both studies contain limitations that preclude strong conclusions. The NTP is presently carrying out additional experiments on the relationship, if any, between fluoride and cancer.

## B.3 Mechanisms of Action

A number of mechanisms are involved in the toxicity of fluoride to bone. Fluoride ions are incorporated into bone by substituting for hydroxyl groups in the carbonate-apatite structure to produce hydroxy-fluorapatite, thus altering the mineral structure of the bone (Chachra et al. 1999). Unlike hydroxyl ions, fluoride ions reside in the plane of the calcium ions, resulting in a structure that is electrostatically more stable and structurally more compact (Grynpas and Rey 1992). Following administration of fluoride, there is a shift in the mineralization profile towards higher densities and increased hardness (Chachra et al. 1999). Although fluoride administration is associated with an increase in bone mass, in vivo and in vitro animal studies have found a negative association between fluoride-induced new bone mass and bone strength, suggesting that the quality of the new bone was impaired by the fluoride (ATSDR 2001d). Because bone strength is thought to derive mainly from the interface between the collagen and the mineral (Catanese and Keavney 1996), alteration in mineralization probably affects strength. The wider crystals, which are formed after fluoride exposure, are presumably not associated with collagen fibrils and thus, do not contribute to mechanical strength. Turner et al. (1997) found that the crystal width was inversely correlated with bending strength of the femur. Thus, although there is an increase in hardness and bone mass and unaltered structure, the mechanical strength of bone is decreased (Chachra et al. 1999).

In addition to the physicochemical effect of fluoride on the bone, at high doses, fluoride can be mitogenic to osteoblasts (ATSDR 2001d) and inhibitory to osteoclasts. The osteoblasts are still active, although there are fewer plump, cuboidal, highly secretory osteoblasts; whereas fluoride is mitogenic to osteo-blastic precursors (Bonjour et al. 1993), it is toxic to individual osteoblasts at the same concentration (Chachra et al. 1999). The effect of fluoride on osteoclasts is not well understood; it appears that fluoride decreases the amount of bone resorbed by osteoclasts (Chachra et al. 1999).

Studies in humans and animals suggest that the effect of fluoride on bone strength is biphasic. In rats administered 1–128 ppm fluoride as sodium fluoride in drinking water for 16 weeks, both increases and decreases in bone strength were found; the maximum femoral bone strength occurred at 16 ppm (Turner et al. 1992). A biphasic relationship between femoral bone strength and bone fluoride content was found. The biphasic nature of bone effects is supported by data from clinical trials in women with post-menopausal osteoporosis (Haguenauer et al. 2000). The meta-analyses of 12 studies found a significant increase in the relative risk of nonvertebral fractures in subjects ingesting high doses of fluoride; in subjects administered low fluoride doses or slow-release formulations, there was no effect on nonvertebral fractures. Similarly, there was no effect on vertebral fracture risk in high fluoride dose subjects, but a decrease in this risk in subjects administered low fluoride doses or slow-release formulations was found.

Fluoride has been shown to interfere with glycolysis. Because the central nervous system relies heavily on this energy source, hypotheses have been advanced as to a mechanism for fluoride effects on the central nervous system. Although effects on glycolytic enzymes could explain the neuromuscular symptoms seen frequently in cases of fluoride poisoning (e.g., tetany, paresthesia, paresis, convulsions), other studies tend to indicate that hypocalcemia caused by fluoride binding of calcium causes these symptoms.

## B.4 Health Guidelines

ATSDR (2001d) derived an acute inhalation MRL of 0.01 ppm for fluorine, based on a NOAEL of 10 ppm for irritation of the eyes and skin during a 15-minute exposure of volunteers. The NOAEL was adjusted for a 24-hour continuous exposure, and an uncertainty factor of 10 for intrahuman variability was applied to yield the MRL of 0.01 ppm.

ATSDR (2001d) also derived an acute inhalation MRL of 0.03 ppm fluoride for hydrogen fluoride, based on a NOAEL of 98 ppm fluoride for nasal irritation in rats exposed for 60 minutes. The NOAEL was converted to a human equivalent concentration, duration-adjusted, and an uncertainty factor of 30 (3 for animal to human extrapolation using dosimetric adjustment, and 10 for intrahuman variability) to give the MRL of 0.03 ppm fluoride.

An intermediate-duration inhalation MRL of 0.02 ppm fluoride (ATSDR 2001d) was derived for hydrogen fluoride based on a duration-adjusted LOAEL of 0.75 ppm fluoride for slight irritation of the respiratory tract in volunteers exposed to hydrogen fluoride for 15–50 days. An uncertainty factor of 30 (3 for use of a minimal LOAEL and 10 for intrahuman variability) was applied to the LOAEL to derive the MRL of 0.02 ppm fluoride.

No inhalation MRLs were derived for fluorides other than hydrogen fluoride. No chronic inhalation MRLs were derived for fluorine or hydrogen fluoride (ATSDR 2001d).

No oral MRLs were derived for fluorine or hydrogen fluoride (ATSDR 2001d).

No acute or intermediate MRLs were derived for fluoride (ATSDR 2001d).

A chronic-duration oral MRL of 0.06 mg fluoride/kg/day was derived for fluoride (ATSDR 2001d), based on a LOAEL of 0.56 mg fluoride/kg/day for increased fracture rate in osteoporotic postmenopausal women. The MRL was derived by applying an uncertainty factor of 10 for use of a LOAEL in a sensitive human subpopulation.

EPA has derived an oral RfD of 0.06 mg/kg/day for fluoride (ATSDR 2001d), based on a NOAEL of 0.06 mg/kg/day for dental fluorosis in chronically-exposed children (Hodge 1950). An uncertainty factor of 1 was applied to the NOAEL since the study was a chronic study in a sensitive population of humans.

No RfC for fluoride has been derived, and fluoride has not undergone an evaluation of carcinogenic potential by EPA.

## B.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to fluoride were derived for endpoints affected by one or more of the other chemicals in the uranium, fluoride, cyanide, and nitrate mixture that is the subject of this Interaction Profile. The relevant endpoints for this mixture include renal, neurological, and reproductive (testicular) effects. Where data are available, chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001c, Section 2.3.2). The derivations are based on data presented in ATSDR (2001d).

### Musculoskeletal Effects

A number of human studies have investigated the toxicity, particularly potential skeletal toxicity, of fluoride (for review of these studies, see ATSDR 2001d). The vast majority of these studies were ecological studies examining the possible relationship between fluoride in drinking water and the occurrence of hip fractures. These studies, as well as retrospective cohort studies, have found decreases, increases, and no effect on hip fracture occurrence in communities consuming fluoridated water. Limitations in the study designs of many of these studies preclude using these data to establish a causal relationship between fluoride and risk of hip fractures. In addition to these epidemiology studies, several human experimental studies have examined the effect of fluoride administration for the treatment of osteoporosis. One study found significant increases in lumbar spine and femoral head and trochanter bone mineral density, decreases in radius bone mineral density, no effect on vertebral fracture rate, and increases in nonvertebral fracture rate among postmenopausal women with osteoporosis ingesting a capsule containing 34 mg fluoride/day as sodium fluoride for 4–6 years. Another study did not find any effect on bone mineral density or vertebral or nonvertebral fracture rates among postmenopausal women with spinal osteoporosis ingesting 34 mg fluoride/day as sodium fluoride. A meta-analysis of these data, as well as other clinical studies, found a significant correlation between exposure to high levels of fluoride and an increased relative risk of nonvertebral fractures. The LOAEL of 34 mg fluoride/day (0.56 mg fluoride/kg/day) was selected as the basis of a chronic-duration oral MRL for fluoride. The MRL of 0.06 mg fluoride/kg/day was derived by dividing the LOAEL by an uncertainty factor of 10 to account for the use of a LOAEL in a sensitive subpopulation.

### Renal Effects

Greenberg (1982) reported a LOAEL of 1.9 mg fluoride/kg/day for degeneration of the nephron in mice exposed to sodium fluoride in the drinking water for 280 days. To this LOAEL, an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for intrahuman variability) was applied to yield a provisional TTD_RENAL_ of 2×10^−2^ mg/kg/day. However, as this value, derived from animal data, is lower than the chronic MRL of 0.06 mg/kg/day, which is based on chronic human data examining the most sensitive known endpoint of fluoride toxicity, the MRL value of 0.06 mg/kg/day was adopted as the TTD_RENAL_ for fluoride.

### Reproductive Effects

In CD rats exposed to sodium fluoride for 60 days in the diet, Araibi et al. (1989) reported a LOAEL of 2.3 mg fluoride/kg/day for alterations in the seminiferous tubule diameter. To this LOAEL, an uncertainty factor of 1,000 (10 for a LOAEL, 10 for animal to human extrapolation, and 10 for intrahuman variability) to yield a provisional TTD_REPRO_ of 2×10^−3^ mg/kg/day. However, as this value, derived from animal data, is lower than the chronic MRL of 0.06 mg/kg/day, which is based on chronic human data examining the most sensitive known endpoint of fluoride toxicity, the MRL value of 0.06 mg/kg/day was adopted as the TTD_REPRO_ for fluoride.

### Neurological Effects

Mullenix et al. (1995) identified a NOAEL of 5.5 mg fluoride/kg/day and a LOAEL of 7.5 mg fluoride/kg/day for alterations in spontaneous behavior in Sprague-Dawley rats exposed to sodium fluoride in the drinking water for 6 weeks. To this LOAEL, an uncertainty factor of 1,000 (10 for a LOAEL, 10 for animal to human extrapolation, and 10 for intrahuman variability) to yield a provisional TTD_NEURO_ of 5×10^−3^ mg/kg/day. However, as this value, derived from animal data, is lower than the chronic MRL of 0.06 mg/kg/day, which is based on chronic human data examining the most sensitive known endpoint of fluoride toxicity, the MRL value of 0.06 mg/kg/day was adopted as the TTD_NEURO_ for fluoride.

### Summary (TTDs for Fluoride)

TTD_RENAL_ = 0.06 mg/kg/day

TTD_REPRO_ = 0.06 mg/kg/day

TTD_NEURO_ = 0.06 mg/kg/day

## B.6 References

Araibi AA, Yousif WH, Al-Dewachi OS. 1989. Effect of high fluoride on the reproductive performance of the male rat. J Biol Sci Res 20:19–30. (As cited in ATSDR 2001d.)
ATSDR. 2001c. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001d. Toxicological profile for fluorine, hydrogen fluoride, and fluorides. Draft for public comment. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
Bonjour JP, Caverzasio J, Rizzoli R. 1993. Effect of fluoride on bone cells. Res Clin Forums 15:9–12. (As cited in ATSDR 2001d.)
Bucher JR, Hejtmancik MR, Toft JD II, . 1991. Results and conclusions of the national toxicology program’s rodent carcinogenicity studies with sodium fluoride. Int J Cancer 48:733–737.2071234
Catanese J, Keaveny TM. 1996. Role of collagen and hydroxyapatite in the mechanical behavior of bone tissue. J Bone Miner Res 11:S295. (As cited in ATSDR 2001d.)
Chachra D, Turner CH, Dunipace AJ, . 1999. The effect of fluoride treatment on bone mineral in rabbits. Calcif Tissue Int 64:345–351. (As cited in ATSDR 2001d.)10089229
Collings GH, Fleming RBL, May R. 1951. Absorption and excretion of inhaled fluorides. AMA Arch Ind Hyg Occup Med 4:585–590. (As cited in ATSDR 2001d.)14877318
Eichler HG, Lenz K, Fuhrmann M, . 1982. Accidental ingestion of NaF tablets by children. Int J Clin Pharmacol Ther Toxicol 20:334–338.7107087
Ekstrand J, Ehrnebo M. 1983. The relationship between plasma fluoride, urinary excretion rate, and urine fluoride concentrations in man. J Occup Med 25:745–748. (As cited in ATSDR 2001d.)6631559
Ekstrand J, Alván G, Boréus LO, . 1977. Pharmacokinetics of fluoride in man after single and multiple oral doses. Eur J Clin Pharmacol 12:311–317. (As cited in ATSDR 2001d.)590317
Greenberg SR. 1982. The effect of chronic fluoride exposure on the liver: Part I. The parenchyma. Proc Inst Med Chic 39:53–54. (As cited in ATSDR 2001d.)
Grynpas MD, Rey C. 1992. The effect of fluoride treatment on bone mineral crystals in the rat. Bone 13:423–429. (As cited in ATSDR 2001d.)1476820
Haguenauer D, Welch V, Shea B, . 2000. Fluoride for the treatment of postmenopausal osteoporotic fractures: A meta-analysis. Osteoporos Int 11:727–38. (As cited in ATSDR 2001d.)11148800
Halton DM, Dranitsaris P, Baynes CJ. 1984. Toxicity levels to humans during acute exposure to hydrogen fluoride. Atomic Energy Control Board, Ottawa, Canada. Report No. CA8508058. (As cited in ATSDR 2001d.)
Hodge HC. 1950. The concentration of fluorides in drinking water to give the point of minimum caries with maximum safety. J Am Dent Assoc 40:436. (As cited in ATSDR 2001d.)
Keplinger ML, Suissa LW. 1968. Toxicity of fluorine short-term inhalation. Am Ind Hyg Assoc J 29(1):10–18.5667185
Likins RC, McClure FJ, Steere AC. 1962. Urinary excretion of fluoride following defluoridation of a water supply. In: McClure FJ, ed. Fluoride drinking waters. Bethesda, MD: U.S. Department of Health, Education and Welfare, Public Health Service, National Institute of Dental Research, 421–423. (As cited in ATSDR 2001d.)
Lim JK, Renaldo GJ, Chapman P. 1978. LD50 of stannous fluoride, sodium fluoride and sodium mono-fluoro phosphate in the mouse compared to the rat. Caries Res 12:177–179. (As cited in ATSDR 2001d.)272954
Maurer JK, Cheng MC, Boysen BG, . 1990. 2-Year carcinogenicity study of sodium fluoride in rats. J Nat Cancer Inst 82(13):118–1126.
McClure FJ, Mitchell HH, Hamilton TS, . 1945. Balances of fluorine ingested from various sources in food and water by five young men. J Ind Hyg Toxicol 27:159–170. (As cited in ATSDR 2001d.)
Morris JB, Smith FA. 1982. Regional deposition and absorption of inhaled hydrogen fluoride in the rat. Toxicol Appl Pharmacol 62:81–89. (As cited in ATSDR 2001d.)7064158
Mullenix PJ, Denbesten PK, Shunior A, . 1995. Neurotoxicity of sodium fluoride in rats. Neurotoxicol Teratol 17(2):169–177.7760776
NTP. 1990. NTP technical report on the toxicology and carcinogenesis studies of sodium fluoride in F344/N Rats and B6C3F_1_ mice (drinking water studies). Washington, DC: Department of Health, Education, and Welfare, National Toxicology Program. NTP TR 393, NIH publication no. 90-2848.
Rye WA. 1961. Fluorides and phosphates - clinical observations of employees in phosphate operation. International Congress on Occupational Health, July 25–29, 1960. 361–364. (As cited in ATSDR 2001d.)
Spencer H, Lewin I, Wistrowski E, . 1970. Fluoride metabolism in man. Am J Med 49:807–813. (As cited in ATSDR 2001d.)5006619
Stokinger HE. 1949. Toxicity following inhalation of fluorine and hydrogen fluoride. In: Voegtlin C, Hodge HC, eds. Pharmacology and toxicology of uranium compounds. New York NY: McGraw Hill Book Company, 1021–1057.
Trautner K, Einwag J. 1987. Factors influencing the bioavailability of fluoride from calcium-rich, health food products and CaF_2_ in man. Arch Oral Biol 32(6):401–406. (As cited in ATSDR 2001d.)3479080
Turner CH, Akhter MP, Heaney RP. 1992. The effects of fluoridated water on bone strength. J Orthop Res 10(4):581–587. (As cited in ATSDR 2001d.)1613632
Turner CH, Garetto LP, Dunipace AJ, . 1997. Fluoride treatment increased serum IGF-1, bone turnover, and bone mass, but not bone strength, in rabbits. Calcif Tissue Int 61:77–83. (As cited in ATSDR 2001d.)9192519
Whitford GM, Pashley DH. 1984. Fluoride absorption: The influence of gastric acidity. Calcif Tissue Int 36:302–307. (As cited in ATSDR 2001d.)6088010