# APPENDIX A Background Information for Uranium

## A.1 Toxicokinetics

Studies conducted in human adults indicate that gastrointestinal absorption of ingested soluble uranium salts is <5%. On the basis of studies in animals, absorption of more water soluble uranyl compounds is greater than less soluble oxides and tetrahalide compounds. Studies in animals also provide evidence that gastrointestinal absorption of uranium may be increased by fasting and diets deficient in iron, and is higher in neonates than in adults. The rate of absorption of uranium compounds deposited in the respiratory tract varies with solubility of the uranium compound; more water soluble uranyl compounds are absorbed more readily than less soluble oxides and tetrahalide. Absorbed uranium appears to distribute initially to kidney, liver, and other soft tissues; however, under steady state conditions, the kidneys and skeleton contain most of the uranium in the body. Most of the uranium entering the kidney and soft tissue is lost over a period of days, but a small amount is retained for years. Uranium is lost from bone in multiple phases having half-lives of days, months, and years. As a result, the major depot for uranium is the bone within months or years after exposure ceases. Uranium is not known to be metabolized. The uranyl ion forms complexes with bicarbonate, citrate, and other soluble anionic species, and binds to proteins in tissue and plasma. Absorbed uranium is excreted primarily in urine (ATSDR 1999b).

Uranium radioisotopes, although they emit alpha radiation, behave in a chemically identical manner relative to stable uranium isotopes. As such, no differences in the kinetics of stable and radioactive uranium isotopes are expected, and the kinetics of distribution of the emitted radiation, which has a very short path length, can be predicted based on the pharmacokinetic parameters of stable uranium.

## A.2 Health Effects

Absorbed uranium is nephrotoxic. Clinical case studies indicate that uranium can produce nephrotoxic effects in humans (ATSDR 1999b; Lussenhop et al. 1958). Epidemiological studies have found indications of possible nephrotoxicity (e.g., tubular proteinuria, aminoaciduria, glucosuria, and enzymuria) in uranium mill workers and in populations exposed to uranium in well water (ATSDR 1999b). Nephrotoxicity has been observed in a variety of animal species including dogs, rabbits, and rats exposed to uranyl salts (e.g., uranyl acetate, fluoride or nitrate) by the oral route, in rats exposed by the inhalation route, in dogs, rabbits, and rats subjected to whole-body exposures to air-borne uranium, or after parenteral dosing (reviewed in ATSDR 1999b and Diamond 1989). The functional and morphological changes that have been observed in these studies are reasonably consistent across species and uranyl salts; these include, depending on the dosage and timing of observations, lesions of the glomerulus and renal proximal tubule and a variety of related functional impairments, including decreased glomerular filtration and renal blood flow, glucosuria and amino aciduria, proteinuria, and enzymuria. Studies of rats and rabbits have shown that ingestion of soluble uranium salts can produce histological changes in the thyroid gland and liver lesions in addition to renal lesions (ATSDR 1999b).

The studies reported in Maynard and Hodge (1949) and Maynard et al. (1953) were conducted as part of the health physics program of the Manhattan Project. The reporting of study outcomes focused primarily on three indicators of toxicity: growth depression, mortality, and nephrotoxicity, and, despite the above limitations, provided data on the relative toxicity of a wide variety of water soluble and relatively water insoluble uranium compounds. In general, studies of rats (the rat was the most extensively explored animal model) demonstrated that the more water soluble compounds (e.g., UO_2_F_2_, UO_s_(CH_3_COO)_2_·2H2O, UO_2_(NO_3_)_2_·6H_2_O, UO_4_) have higher toxic potencies than the relatively water insoluble uranium compounds (e.g., UO_2_, UO_3_, U_3_O_8_). Yuile (1973) summarized the relative potency for selected uranium compounds as follows, based on a comparison of the dietary concentrations (%) that produced equal body weight depressions in the chronic rat studies: UO_2_F_2_, 0.25% (155 mg U/kg-day); UO_2_(NO_3_)_2_·6H_2_O, 1% (380 mg U/kg-day); UF_4_, 20% (12,000 mg U/kg-day); and UO_2_, >20% (>14,000 mg U/kg-day).

Inhaled uranium particulate can produce lung disease. A relatively large body of epidemiological literature exists on the topic of health outcomes associated with working in the uranium ore mining industry (e.g., Bruske-Hohlfeld et al. 1997; Hnizdo et al. 1997; Hornung et al. 1998; Roscoe 1997; Roscoe et al. 1995). These studies have shown excess risks of lung cancer and other respiratory tract diseases among miners. Uranium exposures in these populations is to a complex mixture of radon gas and daughter isotopes as well as to airborne dusts containing a variety of uranium compounds including various water insoluble uranium oxides. Exposures to radon daughter isotopes are thought to be major contributors to the increased risk of diseases of the respiratory tract, including cancer, in uranium miners.

Health outcomes associated with working in the uranium processing industry also have been studied. Here again, exposure in these industries is primarily to dusts of relatively insoluble uranium compounds and, possibly, to aerosols of more soluble uranium compounds. Internal exposure to alpha radiation may be a major contributor to increased lung cancer risks, which have been reported in some studies. Chronic exposures to uranium dioxide produced nephrotoxic changes and lung fibrosis in dogs and monkeys (ATSDR 1999b).

A small number of studies of the reproductive and developmental effects of uranyl salts have been reported (ATSDR 1999b; Paternain et al. 1989). The results of these studies suggest that maternal exposures to uranyl acetate during pregnancy can be maternally toxic and fetotoxic.

Only limited data exist on the toxicity of uranium radiation. From the standpoint of noncancer effects, the effects noted in studies of uranium, even radioisotopes of uranium, are believed to be solely chemical (ATSDR 1999b). Although radiation exposure has been generally assumed to be carcinogenic at all dose levels, no correlation has been established at low doses such as occur from exposure to natural radiation background levels. This is largely attributable to two factors: (1) it is difficult to construct and obtain meaningful data from epidemiological studies where exposure is near background exposure levels, and (2) the data are not statistically significant enough to substantiate a detectable health impact.

## A.3 Mechanisms of Action

Mechanisms of uranium-induced nephrotoxicity have been extensively explored in animal models (reviewed in Diamond 1989). Decreased glomerular filtration rate, proteinuria, impairment of tubular function, and tubular injury are prominent features of nephrotoxicity in animals exposed to uranyl compounds. Mechanisms for decreased glomerular filtration appear to involve multiple factors including changes in renal plasma flow, glomerular capillary hydrostatic pressure, tubular hydraulic pressure, and glomerular ultrafiltration coefficient. Tubular impairments include glucosuria, amino aciduria, enzymuria, and osmotic diuresis. Prominent features of tubular injury are initial necrosis of the terminal segments of the proximal tubule with subsequent involvement of the distal tubule. Tubular impairment may represent a combination of direct effects of uranyl ion on transport proteins and the effects of tubular necrosis. Mechanisms of proteinuria have not been elucidated, and may have a glomerular and/or tubular origin.

Mechanisms of liver lesions and histological changes in the thyroid observed in rabbits and rats have not been elucidated. Mechanisms of uranium-induced lung disease are not completely understood. Involvement of inflammation related to the deposition of insoluble particulates in the lung is thought to be a contributor where the inhalation exposure is to insoluble uranium compounds. Radiogenic cancers may also arise from local irradiation of lung and lymph tissue from alpha-activity of uranium isotopes. Ionizing radiation, including alpha particles such as are emitted from uranium isotopes, is believed to result in ionization events leading to a number of harmful cellular processes, including free radical formation, lipid peroxidation, and deoxyribonucleic acid (DNA) damage. A thorough review of the mechanisms of ionizing radiation is found in the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999a).

## A.4 Health Guidelines

ATSDR (1999b) has derived an MRL of 8.0×10^−3^ mg U/m^3^ for intermediate-duration inhalation exposure to insoluble compounds of uranium based on a no-observed-adverse-effect level (NOAEL) of 1.1 mg U/m^3^ for renal effects in dogs (Rothstein 1949b).

ATSDR (1999b) has derived an MRL of 4.0×10^−4^ mg U/m^3^ for intermediate-duration inhalation exposure to soluble compounds of uranium based on a lowest-observed-adverse-effect level (LOAEL) of 0.15 mg U/m^3^ for renal effects in dogs (Rothstein 1949a).

ATSDR (1999b) has derived an MRL of 3.0×10^−4^ mg U/m^3^ for chronic-duration inhalation exposure (365 days or more) to soluble compounds of uranium based on a NOAEL of 0.05 mg U/m^3^ for renal effects in dogs (Stokinger et al. 1953).

ATSDR (1999b) has derived an MRL of 2.0×10^−3^ mg/kg/day for intermediate-duration oral exposure to soluble compounds of uranium based on a LOAEL of 0.05 mg U/kg/day for renal effects in rabbits (Gilman et al. 1998). This MRL was considered to be protective for chronic exposures as well.

EPA established a chronic oral RfD of 3×10^−3^ mg U/kg-day for soluble uranium salts (IRIS 2002). The RfD is based on weight loss and nephrotoxicity in rabbits observed in a 30-day feeding study (Maynard and Hodge 1949). EPA (IRIS 2002) has not established a chronic inhalation reference concentration (RfC) or cancer risk assessment for uranium compounds.

EPA (1995) has established slope factors for carcinogenicity from ingestion or inhalation of radioisotopes of uranium (EPA 1995). EPA (1999) also has established risk coefficients for radiogenic cancer morbidity and mortality from inhalation, tap water, and dietary intakes of radioisotopes of uranium.

## A.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to uranium were derived for endpoints affected by one or more of the other chemicals in the uranium, fluoride, cyanide, and nitrate mixture that is the subject of this Interaction Profile. The relevant endpoints for this mixture include renal, neurological, and reproductive (testicular) effects. Where data are available, chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001c, Section 2.3.2). Of the endpoints of concern for the mixture, data are available only for renal effects of uranium. The derivations are based on data presented in ATSDR (1999b). Due to inadequate data, TTDs were not derived for uranium radiation.

### Renal Effects

ATSDR (1999b) has derived an MRL of 2.0×10^−3^ mg/kg/day for intermediate-duration oral exposure, and stated that this MRL is likely to be protective for chronic-duration oral exposure, to soluble compounds of uranium based on a LOAEL of 0.05 mg U/kg/day for renal effects in rabbits (Gilman et al. 1998). The MRL was derived by applying an uncertainty factor of 30 (3 for use of a minimal LOAEL and 10 for intrahuman variability) to the LOAEL.

### Summary (TTDs for Uranium)

MRL_RENAL_ = 2 × 10^− 3^ mg / kg / day

## A.6 References

ATSDR. 1999a. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 1999b. Toxicological profile for uranium. U.S. Department of Health and Human Services. Agency for Toxic Substances and Disease Registry. Atlanta, GA.
ATSDR. 2001c. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Brüske-Hohlfeld I, Mohner M, Wichmann H-E. 1997. Predicted number of lung cancer cases in Germany among former uranium miners of the Wismut. Health Phys 72(1):3–9.8972821
Diamond GL. 1989. Biological consequences of exposure to soluble forms of natural uranium. Radiat Prot Dosim 26:23–33.
EPA. 1995. Health effects assessment summary tables. U.S. Environmental Protection Agency. EPA 544/R-95-036.
EPA. 1999. Cancer risk coefficients for environmental exposure to radionuclides. Federal Guidance Report No. 13. U.S. Environmental Protection Agency. EPA 402/R-99-001.
Gilman AP, Villeneuve DC, Secours VE, . 1998. Uranyl nitrate: 91-day toxicity studies in the New Zealand white rabbit. Toxicol Sci 41:129–137.9520347
Hnizdo E, Murray J, Klempman S. 1997. Lung cancer in relation to exposure to silica dust, silicosis and uranium production in South African gold miners. Thorax 52:271–275.9093345
Hornung RW, Deddens JA, Roscoe RJ. 1998. Modifiers of lung cancer risk in uranium miners from the Colorado plateau. Health Phys 74(1):12–21.9415577
IRIS. 2002. Integrated risk information system (IRIS). U.S. Environmental Protection Agency. http://www.epa.gov/iris/.
Lussenhop AJ, Gallimore JC, Sweet WH, . 1958. The toxicity in man of hexavalent uranium following intravenous administration. Am J Roentgenol Radium Ther Nucl Med 79:83–100.
Maynard EA, Hodge HC. 1949. Studies of the toxicity of various uranium compounds when fed to experimental animals. In: Voegtlin C, HC Hodge, eds. Pharmacology and toxicology of uranium compounds with a section on the pharmacology and toxicology of fluorine and hydrogen fluoride. New York NY: McGraw-Hill Book Co., Inc, 309–376.
Maynard EA, Downs WL, Hodge HC. 1953. Oral toxicity of uranium compounds. In: Voegtlin C, HC Hodge, eds. Pharmacology and toxicology of uranium compounds. Part III. Chronic studies. New York NY: McGraw-Hill Book Co., Inc, 1221–1369.
Paternain JL, Domingo JL, Ortega A, . 1989. The effects of uranium on reproduction, gestation, and postnatal survival in mice. Ecotoxicol Environ Saf 17:291–296.2743917
Roscoe RJ. 1997. An update of mortality from all causes among white uranium miners from the Colorado plateau study group. Am J Ind Med 31:211–222.9028438
Roscoe RJ, Deddens JA, Salvan A, . 1995. Mortality among Navajo uranium miners. Am J Pub Health 85(4):535–540.7702118
Rothstein A. 1949a. Pharmacology and toxicology of uranium compounds. McGraw-Hill Book Company, Inc., 548–560. (As cited in ATSDR 1999b.)
Rothstein A. 1949b. Pharmacology and toxicology of uranium compounds. McGraw-Hill Book Company, Inc., 614–621. (As cited in ATSDR 1999b.)
Stokinger HE, Baxter RC, Dygert HP, . 1953. Toxicity following inhalation for 1 and 2 years. In: Voegtlin C, HC Hodge, eds. Pharmacology and toxicology of uranium compounds. New York NY: McGraw-Hill Book Co., Inc, 1371–1776.
Yuile CL. 1973. Animal experiments. In: Hodge HC, JN Standard, JB Hursh, eds. Uranium plutonium, transplutonium elements. New York, NY: Springer-Verlag, 164–196.