# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ATSDR: Agency for Toxic Substances and Disease Registry
ATP/ADP: adenosine triphosphate/adenosine diphosphate
BINWOE: binary weight-of-evidence
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
DNA: deoxyribonucleic acid
DOE: Department of Energy
DT: Division of Toxicology
EPA: Environmental Protection Agency
Fe: iron
FQPA: Food Quality Protection Act of 1996
IARC: International Agency for Research on Cancer
ICRP: International Commission on Radiological Protection
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LC_50_: 50% lethal concentration
LD_50_: 50% lethal dose lowest-observed-adverse-effect level
mg: milligram
MRL: Minimal Risk Level
NADH: nicotinamide adenine dinucleotide phosphate (reduced form)
NADPH: nicotinamide adenine dinucleotide phosphate (oxidized form)
NOAEL: no-observed-adverse-effect level
NPL: National Priorities List
NTP: National Toxicology Program
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic/pharmacodynamic
ppm: parts per million
RfC: reference concentration
RfD: reference dose
TTD: target-organ toxicity dose
μmol: micromole
UO_2_F_2_: uranyl fluoride
U.S.: United States
WOE: weight-of-evidence
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to