# 5 References

*Cited in text

Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. Goldfrank’s toxicological emergencies. Stamford, CT: Appleton & Lange, 1429–1449.
ACGIH. 2003. 2003 TLVs and BELs. Threshold limit values for chemical substances and physical agents. Biological exposure indices. American Conference of Governmental Industrial Hygienists, Cincinnati, OH.
*Abd-Elraof TK, Dauterman WC, Mailman RB. 1981. In vivo metabolism and excretion of propoxur and malathion in the rat: Effect of lead treatment. Toxicol Appl Pharmacol 59:324–330.7256771
*Abdelsalam EB, Ford EJ. 1987. The effect of induced liver, kidney and lung lesions on the toxicity of levamisole and diazinon in calves. J Comp Pathol 97(6):619–627.3443686
Alam MK, Maughan OE. 1992. The effect of malathion, diazinon, and various concentrations of zinc, copper, nickel, lead, iron, and mercury on fish. Biol Trace Elem Res 34(3):225–236.1384613
Alexander BH, Checkowaym H, van Netten C, 1996. Semen quality of men employed at a lead smelter. Occup Environ Med 53:411–416. (As cited in ATDSR 2005.)8758037
Allen P. 1994. Mercury accumulation profile and their modification by interaction with cadmium and lead in the soft tissues of the cichlid Oreochromis aureus. Bull Environ Contam Toxicol 53(5):684–692.7833604
Allen P. 1995a. Long-term mercury accumulation in the presence of cadmium and lead in Oreochromis aureus (Steindachner). J Environ Sci Health B 30(4):549–567.7797820
Allen P. 1995b. Soft-tissue accumulation of lead in the Blue Tilapia, Oreochromis aureus (Steindachner), and the modifying effects of cadmium and mercury. Biol Trace Elem Res 50(3):193–208.8962791
Amr M, Allam M, Osmaan AL, 1993. Neurobehavioral changes among workers in some chemical industries in Egypt. Environ Res 63(2):295–300.8243423
Anderson H, Falk C, Hanrahan L, 1998. Profiles of Great lakes critical pollutants: A sentinel analysis of human blood and urine. Environ Health Perspect 106(5):279–289.9560354
*ATSDR. 1997. Toxicological profile for chlorpyrifos. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 2005. Toxicological profile for lead-Draft for Public Comment. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 1999. Toxicological profile for mercury. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001b. Guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*Belles M, Albina ML, Sanchez DJ, 2002. Interactions in developmental toxicology: Effects of concurrent exposure to lead, organic mercury, and arsenic in pregnant mice. Arch Environ Contam Toxicol 42(1):93–98.11706373
*Berkowitz GS, Obel J, Deych E, 2003. Exposure to indoor pesticides during pregnancy in a multiethnic, urban cohort. Environ Health Perspect 111(1):79–84.12515682
Britson CA, Threlkeld St. 1998. Abundance, metamorphosis, developmental, and behavioral abnormalities in Hyla chrysoscelis tadpoles following exposure to three agrichemicals and methyl mercury in outdoor mesocosms. Bull Environ Contam Toxicol 61:154–161.9702370
*Buckley TJ, Liddle J, Ashley DL, 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
Buratti FM, Volpe MT, Meneguz A, 2003. CYP-specific bioactivation of four organophosphorothioate pesticides by human liver microsomes. Toxicol Appl Pharmacol 186(3):143–154.12620367
Burbacher TM, Mohamed MK, Mottett NK. 1988. Methylmercury effects on reproduction and offspring size at birth. Reprod Toxicol 1(4):267–278.
*CDC. 1991. Preventing lead poisoning in young children. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Services, Centers for Disease Control and Prevention. (As cited in ATSDR 2005.)
Chishti MA, Rotkiewicz T. 1992. Ultrastructural alterations produced in cockerels after mercuric chloride toxicity and subsequent interaction with an organophospate insecticide. Arch Environ Contam Toxicol 22(4):445–451.1586206
Chu I, Villeneuve DC, Becking GC, 1981. Subchronic study of a mixture of inorganic substances present in the Great Lakes ecosystem in male and female rats. Bull Environ Contam Toxicol 26(1):42–45.7225621
*Congiu L, Corongiu FP, Dore M, 1979. The effect of lead nitrate on the tissue distribution of mercury in rats treated with methylmercury chloride. Toxicol Appl Pharmacol 51:363–366.531897
Coulston F, Goldberg L, Abraham R, 1972. Final report on safety evaluation and metabolic studies on Dow co. 179(IN151). Inst Exp Pathol Toxicol, Albany Medical College. (As cited in ATSDR 1997.)
Desi I, Nehez M, Siroki O, 2000. Small subchronic doses of the pesticide dimethoate and/or cadmium and lead treatment cause disturbances in the chromosomes of young rats. Cent Eur J Public Health 8:59–60.
*Dieter MP, Ludke JL. 1975. Studies on combined effects of organophosphates and heavy metals in birds. I. Plasma and brain cholinesterase in Coturnix quail fed methyl mercury and orally dosed with parathion. Bull Environ Contam Toxicol 13(3):257–262.1125450
*Dieter MP, Ludke JL. 1978. Studies on combined effects of organophosphates or carbamates and morsodren in birds. II. Plasma and cholinesterase in quail fed morsodren and orally dosed with parathion or carbofuran. Bull Environ Contam Toxicol 19(4):389–395.656640
Egle JL. 1972. Dietary exposures to selected metals and pesticides. Arch Environ Health 24:354–357.5021119
Enserink EL, Maas-Diepeveen JL, Van Leeuwen CJ. 1991. Combined effects of metals: An ecotoxicological evaluation. Water Res 25(6):679–687.
EPA. 1986. Air quality criteria for lead. Research Triangle Park, NC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Health and Environment Assessment, Environmental Criteria and Assessment Office. EPA 600/8–83-028F, 12–34 to 12–37.
EPA. 1994a. Guidance manual for the integrated exposure uptake biokinetic model for lead in children. U.S. Environmental Protection Agency, EPA/540/R-93/081. PB93–963510. (As cited in ATSDR 2005.)
EPA. 1994b. Technical support document: Parameters and equations used in integrated exposure uptake biokinetic model for lead in children (v0.99d). U.S. Environmental Protection Agency. EPA/540/R-94/040. PB94–963505. (As cited in ATSDR 2005.)
EPA. 1996. Bioavailability of lead in soil samples from the Jasper County, Missouri Superfund site. U.S. Environmental Protection Agency Region 8. Document Control No. 04800–030-0161. (As cited in ATSDR 2005.)
*EPA. 2000a. Chlorpyrifos revised risk assessment and agreement with registrants. Washington, DC: U.S. Environmental Protection Agency. Office of Prevention, pesticides and toxic substances (7506C). http://www.epa.gov/pesticides/op/chlorpyrifos/agreement.pdf. June 2000.
EPA. 2000b. Toxicology chapter for chlorpyrifos. Washington, DC: U.S. Environmental Protections Agency. Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/oppsrrd1/op/chlorpyrifos/rev_tox.pdf. April 18, 2000.
*EPA. 2000c. Human health risk assessment. Chlorpyrifos. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/op/chlorpyrifos/hedrra. June 8, 2000.
*EPA. 2002a. Pesticides: Organophosphates. Chlorpyrifos facts. Washington, DC: U.S. Environmental Protections Agency. http://www.epa.gov/oppsrrd1/REDs/factsheets/chlorpyrifos_fs.htm.
EPA. 2002b. 2002 edition of the drinking water standards and health advisories. Washington, DC: U.S. Environmental Protections Agency. Office of Water. EPA 822-R-02–038.
*Ewald KA, Calabrese EJ. 2001. Lead reduces the nephrotoxicity of mercuric chloride. Ecotoxicol Environ Saf 48(2):215–218.11161697
Farant JP, Wiglield DC. 1987. Interaction of divalent metal ions with normal and lead-inhibited human erythrocytic prophobilinogen syntheses in vitro. Toxicol Appl Pharmacol 89:9–18.3590192
FAO/WHO. 1999. Pesticide residues in food. Toxicological evaluations. International Programme on Chemical Safety. Food and Agriculture Organization & World Health Organization, 1–61. http://www.inchem.org/documents/jmpr/jmpmono/v99pr03.htm.
*Garber B, Wel E. 1972. Adaptation to the toxic effects of lead. Am Ind Hyg Assoc J 33(11):756–760.4661867
Gorell JM, Johnson CC, Rybicki BA, 1997. Occupational exposure to metals as risk factors for Parkinson's disease. Neurology 48:650–658.9065542
Gorell JM, Johnson CC, Rybicki BA, 1999. Occupational exposure to manganese, copper, lead, iron, mercury and zinc and the risk of Parkinson's disease. Neurotoxicology 20(2–3):239–248.10385887
Grandjean P, Weihe P, Needham LL, 1995. Relation of a seafood diet to mercury, selenium, arsenic, and polychlorinated biphenyl and other organochlorine concentrations in human milk. Environ Res 71:29–38.8757236
*Hapke HJ, Youssef S, Omer OH. 1978. Modification of the alkylphosphate toxicity in lead-contaminated rats (in German). Dtsch Tieraerztl Wochenschr 85(11):441–444.
Hultman P, Enestrom S. 1992. Dose-response studies in murine mercury-induced autoimmunity and immune-complex disease. Toxicol Appl Pharmacol 113:199–208.1532866
Hultman P, Johansson U, Turley SJ, 1994. Adverse immunological effects and autoimmunity induced by dental amalgam and alloy in mice. FASEB J 8:1183–1190.7958626
IARC. 1987. IARC monographs on the evaluation of carcinogenic risk to humans. International Agency for Research on Cancer, World Health Organization. Supplement 7, Vol. 1–47.
IARC. 2003. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs Volumes 1–82 (a total of 885 agents, mixtures and exposures). International Agency for Research on Cancer. http://193.51.164.11/moneeval/crthall.html. January 2004.
Ilback N-G. 1991. Effects of methyl mercury exposure on spleen and blood natural killer (NK) cell activity in the mouse. Toxicology 67:117–124.2017762
Ilback N-G, Sunderberg J, Oskarsson A. 1991. Methyl mercury exposure via placenta and milk impairs natural killer (NK) cell function in newborn rats. Toxicol Lett 58:149–158.1949074
*Institoris L, Siroki O, Desi I, 1999. Immunotoxicology examination of repeated dose combined exposure by dimethoate and two heavy metals in rats. Hum Exp Toxicol 18(2):88–94.10100021
*Institoris L, Siroki O, Underger U, 2001. Immunotoxicological investigations on rats treated subacutely with dimethoate, As3+ and Hg2+ in combination. Hum Exp Toxicol 20(7):329–336.11530831
*IRIS. 2004. Integrated Risk Information Systems. U.S. Environmental Protection Agency. http://www.epa.gov.iris.
Iturri SJ, Pena A. 1986. Heavy metal-induced inhibition of active transport in the rat small intestine in vitro. Interaction with other ions. Comp Biochem Physiol C 84(2):363–368 2874953
Jordan SA, Bhatnager MK. 1990. Hepatic enzyme activity after combined administration of methylmercury, lead and cadmium in the Pekin duck. Bull Environ Contam Toxicol 44:623–628.2157510
*Jordan SA, Bhatnager MK, Dettger WJ. 1990. Combined effects of methylmercury, lead, and cadmium on hepatic metallothionein and metal concentrations in the Pekin duck. Arch Environ Contam Toxicol 19:886–891.
Krishnan K, Brodeur J. 1994. Toxic interactions among environmental pollutants: Corroborating laboratory observations with human experience. Environ Health Perspect 102:11–17.
Kukowski A, Shubat P, Stroebel C. 2001. Assessment of children's risks from individual and combined neurotoxicants. Neurotoxicology 22(1):144.
Lasley SM Gilbert ME. 1999. Lead inhibits the rat N-methyl-D-aspartate receptor channel by binding to a site distinct from the zinc allosteric site. Toxicol Appl Pharmacol 159:224–233.10486309
Lewis M, Worobey J, Ramsay DS, 1992. Prenatal exposure to heavy metals: Effect on childhood cognitive skills and health status. Pediatrics 89(6):1010–1015.1594339
Manzo L, Castoldi AF, Coccini T, 1995. Mechanisms of neurotoxicity: Applications to human biomonitoring. Toxicol Lett 77:63–72.7618170
Marlowe M, Cossairt A, Moon C, 1985a. Main and interaction effects of metallic toxins on classroom behavior. J Abnorm Child Psychol 13(2):185–198.4008752
Marlowe M, Stellern J, Errera J, 1985b. Main and interaction effects of metal pollutants on visual-motor performance. Arch Environ Health 40(4):221–225.4051577
McMurray ST, Lochmiller RL, McBee K, 1999. Indicators of immunotoxicity in populations of cotton rats (Sigmodon hispidus) inhabiting an abandoned oil refinery. Ecotoxicol Environ Saf 42(3):223–235.10090811
Mohamed M, Burbacher T, Mottett N. 1987. Effect of methyl mercury on testicular functions in Macaca fascicularis monkeys. Pharmacol Toxicol 60(1):29–36.3562387
Mukerjee S, Ellenson WD, Lewis RG, 1997. An environmental scoping study in the lower Rio Grande Valley of Texas. III. Residential microenvironmental monitoring for air, house dust, and soil. Environ Int 23:657–673.
Nagymajtenyi L, Schulz H, Papp A, 1997. Developmental neurotoxic effects of environmental pollutants (heavy metals + organophosphates) in animal experiments. Neurotoxicology 18(3):876.
*Nagymajtenyi L, Schultz H, Papp A, 1998. Developmental neurotoxicology effects of lead and dimethoate in animal experiments. Neurotoxicology 19(4–5):617–622.9745920
Nagymajtenyi L, Desi I, Schulz H, 2000a. Developmental effects of combined lead, mercury, and ethanol exposure on neurophysiological processes in rats. Neurotoxicology 21(4):628–629.
*Nagymajtenyi L, Desi I, Papp A, 2000b. Experimentally induced functional changes of the nervous system caused by subchronic combined administration of heavy metals and on organophosphate pesticide. Cent Eur J Public Health 8:64–65.10943472
Needleman HL, Gatsonis CA. 1990. Low-level lead exposure and the IQ of children: A meta-analysis of modern studies. J Am Med Assoc 263(5):673–678.
Newland MC. 1994. The value of behavioral mechanisms in studies of developmental neurotoxicology. Neurotoxicol Teratol 16(3):313.
NTP. 2001. 9^th^ report on carcinogens. Research Triangle Park, NC: U.S. Department of Health and Human Services. National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. September 11, 2001.
NTP. 2003. 10^th^ report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Nublien F, Feicht EA, Schulte-Hostede S, 1995. Exposure analysis of the inhabitants living in the neighborhood of a mercury-contaminated industrial site. Chemosphere 30(12):2241–2248.7620851
Oskarrsson A, Palminger HI, Sundberg J, 1998. Risk assessment in relation to neonatal metal exposure. Analyst 123(1):19–23.9581014
Park JD, Liu Y, Klassen CD. 2001. Protective effect of metallothionein against the toxicity of cadmium and other metals. Toxicology 21(2–3):93–100.
Parkinson A. 1996. Biotransformation of xenobiotics. In: Klassen CD, ed. Cassarett and Doull’s Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Peakall DB. 1996. Disrupted patterns of behavior in natural populations as an index of ecotoxicity. Environ Health Perspect Suppl 104(2):331–335.
*Phillips WE, Hatina G, Villeneuve DC, 1973. Chronic ingestion of lead and the response of the immature rat to parathion. Bull Environ Contam Toxicol 9(1):28–36.4780430
Pocock SJ, Smith M, Baghurst P. 1994. Environmental lead and children’s intelligence: A systematic review of the epidemiological evidence. Br Med J 309:1189–1197. (As cited in ATSDR 1999.)7987149
Pope CN, Liu J. 1997. Age-related differences in sensitivity to organophosphorus pesticides. Environ Toxicol Pharmacol 4:309–314.21781839
*Prasada Rao PVV, Jordan SA, Bhatnagar MK. 1989a. Combined nephrotoxicity of methylmercury, lead, and cadmium in Pekin ducks: Metallothionein, metal interactions, and histopathology. J Toxicol Environ Health 26:327–348.2926832
*Prasada Rao PVV, Jordan SA, Bhatnager MK. 1989b. Ultrastructure of kidney of ducks exposed to methylmercury, lead and cadmium in combination. J Environ Pathol Toxicol & Oncology 9(1)19–44.
Prasada Rao PVV, Jordan SA, Bhatnagar MK. 1993. Renal enzyme changes in Pekin ducks (Anas platyrychos) after combined administration of methylmercury, cadmium and lead. Comp Biochem Physiol 106C(3):769–772.
Propst TL, Lochmiller RL, Qualls CW JR, 1999. In situ (mesocosm) assessment of immunotoxicity risks to small mammals inhabiting petrochemical waste sites. Chemosphere 38(5):1049–1067.10028658
Rao PV, Jordan SA, Bhatnagar MK. 1989. Ultrastructure of kidney of ducks exposed to methylmercury, lead, and cadmium in combination. J Environ Pathol Toxicol Oncol 9(1):19–44.2926660
Rocha JBT, Pereira ME, Emanuelli T, 1995. Effect of treatment with mercury chloride and lead acetate during the second stage of rapid postnatal brain growth on d-aminolevulinic acid dehydratase (ALA-D) activity in brain, liver, kidney, and blood of suckling rats. Toxicology 100:27–37.7624881
Ronnback L, Hansson E. 1992. Chronic encephalopathies induced by mercury of lead: Aspects of underlying cellular and molecular mechanisms. Br J Ind Med 49(4):233–240.1571293
*Schubert J, Riley EJ, Tyler SA. 1978. Combined effects in toxicology--a rapid systematic testing procedure: Cadmium, mercury, and lead. J Toxicol Environ Health 4(5–6):763–776.731728
Schwartz J. 1994. Low-level lead exposure and children’s IQ: A meta-analysis and search for a threshold. Environ Res 65:42–55. (As cited in ATSDR 2005.)8162884
Sheerin NS, Monk PN, Aslam M, 1994. Simultaneous exposure to lead, arsenic and mercury from Indian ethnic remedies. Br J Clin Pract 48(6):332–333.7848800
Shenker BJ, Berthold P, Rooney C, 1993. Immunotoxic effects of mercury compounds on human lymphocytes on monocytes. III. Alterations in B-cell function and viability. Immunopharmacol Immunotoxicol 15(1):87–112.8450183
*Sin YM, Wong MK, Low LK. 1985. Effect of lead on tissue deposition of mercury in mice. Bull Environ Contam Toxicol 34(3):438–445.3978282
*Smolen JM, Stone AT. 1997. Divalent metal ion-catalyzed hydrolysis of phosphorothionate ester pesticides and their corresponding oxonates. Environ Sci Technol 31:1664–1673.
Spehar RL, Fiandt JT. 1986. Acute and chronic effects of water quality criteria-based metal mixtures. Environ Toxicol Chem 5(10):917–932.
*Steevens JA, Benson WH. 1999. Toxicological interactions of chlorpyrifos and methyl mercury in the amphipod, Hyalella azteca. Toxicol Sci 52(2):168–177.10630569
*Steevens JA, Benson WH. 2000. Interactions of chlorpyrifos and methyl mercury: A mechanistic approach to assess chemical mixtures. Mar Environ Res 50(1–5):113–117.11460676
*Steevens JA, Benson WH. 2001. Toxicokinetic interactions and survival of Hyalella azteca exposed to binary mixtures of chlorpyrifos, dieldrin, and methyl mercury. Aquat Toxicol 51(4):377–388.11090897
Stohs SJ, Bagchi D. 1995. Oxidative mechanisms in the toxicity of metal ions. Free Radic Biol Med 18(2):321–336.7744317
*Swart Y, Kruger TF, Menkveld R, 1991. Effect of lead and organophosphates on sperm morphology. Arch Androl 26(2):67–70.2036050
Tang J, Cao Y, Rose RL, 2001. Metabolism of chlorpyrifos by human cytochrome P450 isoforms and human, mouse, and rat liver microsomes. Drug Metab Dispos 29(9):1201–1204.11502728
Taylor P. 1996. Anticholinesterase agents. In: Goodman LS, Gilman A, Hardman JG, , eds. Goodmand & Gilman’s the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 161–176.
*Wan B H, Wong MK, Mok CY. 1994. Mercury(II) ion-promoted hydrolysis of some organophosphorus pesticides. Pestic Sci 42:93–99.
*Yoshikawa H, Hisayoshi O. 1982. Interaction of metals and metallothionein. In: Foulkes EC, ed. Biological roles of metallothionein. Amsterdam, Holland: Elsevier North Holland Inc, 11–23.
Zawia NW, Crumpton T, Brydie M, 2000. Disruption of the zinc finger domain: A common target that underlies many of the effects of lead. Neurotoxicology 21(6):1069–1080.11233753
*Zeinali M, Torrents A. 1998. Mercury-promoted hydrolysis of parathion-methyl: Effect of chloride and hydrated species. Environ Sci Technol 32(15):2338–2342.