# SUMMARY

Chlorpyrifos, lead, and mercury/methylmercury were chosen as the subject for this interaction profile because of the likelihood of co-exposure and because of concerns about neurological effects in children co-exposed to these chemicals. Chlorpyrifos is an organophosphorus insecticide widely used for agricultural and indoor and outdoor residential applications in the United States. Its use, however, is being phased out. Mercury (metallic and inorganic) and lead are released to the environment from hazardous waste sites and from mining, smelting, and industrial activities. Metallic and inorganic mercury can be transformed by microorganisms into methylmercury, which bioaccumulates in the food chain. For the general population, and particularly for subsistence fishers and hunters, the most important pathway of exposure to mercury is ingestion of methylmercury in foods. Fish (including tuna, a food commonly eaten by children), other seafood, and marine mammals contain the highest concentrations. Lead, present in the environment primarily as divalent lead compounds, also contaminates the environment due to its release from mining and from deteriorating lead paint and its historical use in gasoline.

No pertinent health effects data or physiologically-based pharmacokinetic (PBPK) models were located for the complete mixture. Therefore, as recommended by ATSDR (2001a) guidance, the exposure-based screening assessment of potential health hazards for this mixture depends on an evaluation of the health effects data and mechanistic data for the individual components and on the joint toxic action and mechanistic data for various combinations of the components. This profile discusses and evaluates the evidence for joint toxic action among binary mixtures of these chemicals. The profile also recommends how to incorporate concerns regarding possible interactions or additivity into public health assessments of people who may be exposed to mixtures of these chemicals.

The primary effect of concern for this mixture is neurological, and the sub-population of concern is children. Neurological effects are the critical effects for chlorpyrifos, lead, and methylmercury, and children are known (for lead and methylmercury) or predicted on the basis of animal studies (for chlorpyrifos) to be more sensitive than adults. Although metallic mercury causes neurological effects when inhaled, this route is of concern primarily for occupational exposure. Children may be exposed to metallic mercury if they play with it after finding it in abandoned warehouses or taking it from school laboratories. Broken thermometers and some electrical switches are other sources of metallic mercury. Some absorption of metallic mercury occurs from dental amalgam fillings, probably following volatilization from the fillings. Clear evidence of adverse effects from this pathway of exposure is lacking, as are joint action studies with the other components of this mixture, so this form of mercury is not considered further in the interaction profile. The critical effect of inorganic mercury is on the kidney, which is not a sensitive target organ for the other components of the mixture.

Recommendations for screening this mixture for potential hazards to public health include estimating the hazard quotients (ratios of exposures to health guidance values) for the individual components. If only one or if none of the components has a hazard quotient that is at least 0.1, no further assessment of the joint toxic action is needed because additivity and/or interactions are unlikely to result in significant health hazard. If the hazard quotients for two or more of the mixture components equal or exceed 0.1, the following procedures are recommended. To screen this mixture for potential neurological health hazard, an endpoint-specific hazard index for neurological effects should be estimated for chlorpyrifos, lead, and methylmercury. The weight-of-evidence (WOE) analysis for interactions among these components indicates that joint toxic action is primarily less than additive or additive and, therefore, does not increase the concern for potential health hazard above that indicated by the hazard index. This diminishes the concern for hazard indexes only slightly above one. Confidence in these WOE analyses ranges from medium to medium-low. A separate hazard quotient is recommended to screen for the renal toxicity of inorganic mercury. The WOE analysis concluded that the influence on the renal toxicity of inorganic mercury by chlorpyrifos may be less than additive and by lead may be greater than additive, but confidence in these conclusions was low and, thus, they have little impact on the assessment of potential hazards.

If the neurological hazard index for chlorpyrifos, lead, and methylmercury is significantly greater than 1, or if the hazard quotient for inorganic mercury is greater than 1, then further evaluation is needed (ATSDR 2001a), using biomedical judgment and community-specific health outcome data. Community health concerns should be considered in further evaluations (ATSDR 1992).

Data needs were identified in this interaction profile especially in the area of mechanistic and toxicological data pertinent to the influence of inorganic mercury on lead’s neurological toxicity. Information is also needed regarding the joint toxic action of the three-component sub-mixture (chlorpyrifos, lead, and methylmercury) of particular concern for neurological effects in children.