# Appendix C Background Information for Mercury and Methylmercury

Mercury exists in the environment as metallic mercury (also called elemental mercury), inorganic mercury compounds (primarily mercuric), and organic mercury compounds (primarily methylmercury). The structure of methylmercury is shown in Appendix D. Metallic and inorganic mercury released into air from mining, smelting, industrial activities, combustion of fossil fuels, and natural processes can be deposited to water and soil, where the mercury is transformed by microorganisms into methylmercury, which bioaccumulates in the food chain, particularly in fish. For the general population, the most important pathway of exposure to mercury is ingestion of methylmercury in foods, with fish, other seafood, and marine mammals containing the highest concentrations (ATSDR 1999). Another source of exposure for the general population is intake of metallic mercury from dental amalgams. Infants can be exposed to inorganic mercury and methylmercury from breast milk, and the developing fetus can be exposed through transplacental transfer of metallic mercury and methylmercury (ATSDR 1999). For residents near mercury-contaminated hazardous waste sites, the following information provides insight into important routes of exposure. Exposure analysis of residents near an abandoned industrial site that had produced various inorganic and organic mercury compounds (and was not located near drinking water sources) indicated that the children were exposed to mercury primarily though soil and dust ingestion (Nublien et al. 1995).

## C.1 Toxicokinetics

In humans, approximately 15% of a trace oral dose of inorganic mercury (mercuric nitrate) was absorbed through the gastrointestinal tract (ATSDR 1999). Qualitative information indicates that ingested mercuric chloride and mercuric sulfide also were absorbed through the gastrointestinal tract of humans. Studies in animals indicate gastrointestinal absorption of inorganic mercury is in the 10–30% range, and depends on intestinal pH, compound dissociation, and other factors. Qualitative evidence indicates that the absorption of mercuric sulfide may be less than that of mercuric chloride. Absorption of inorganic mercury tended to be higher in young animals than in adults. Following absorption from the gastrointestinal tract, inorganic mercury distributes to the liver and kidneys, with the highest concentrations in the kidneys. Although concentrations in brain are substantially lower, mercury was retained longer in brain than in other tissues.

Metallic mercury is volatile and is readily absorbed (approximately 70–80%) through the respiratory tract, and because of its lipophilic nature, it crosses the blood-brain and placental barriers (ATSDR 1999). Retention of mercury from metallic mercury exposure is longest in the brain, based on data from humans. Absorption of metallic mercury through the gastrointestinal tract, however, is negligible (ATSDR 1999).

Results from studies with humans and laboratory animals indicate that methylmercury and its salts (e.g., methylmercuric chloride and methylmercuric nitrate) are readily and completely absorbed by the gastrointestinal tract, but quantitative information on absorption of methylmercury by the respiratory tract is not available (ATSDR 1999). Absorbed methylmercury is widely distributed among tissues, with the kidney showing the highest accumulation of mercury. Mercury from methylmercury can also accumulate in the brain and fetus due to methylmercury’s abilities to penetrate the blood-brain and placental barriers and its conversion in the brain and fetus to the inorganic divalent cation (ATSDR 1999). Excretion of methylmercury and other organic forms of mercury is thought to occur predominantly in the feces through biliary excretion.

Studies with animals indicate that methylmercury, but not inorganic mercury, can be reabsorbed from the gall bladder and the intestine, resulting in a biliary-hepatic cycle that contributes to longer clearance half-times for methylmercury compared with inorganic mercury (ATSDR 1999). Intestinal flora and various mammalian tissues can produce the divalent mercury ion from methylmercury presumably via hydroxyl radicals produced by cytochrome P450 reductase (ATSDR 1999). Inorganic mercury enters an oxidation-reduction equilibrium between itself, mercurous mercury (Hg^+^), and metallic mercury (Hg^0^) (ATSDR 1999).

## C.2 Health Effects

The nervous system is one of the primary sites of toxicity in humans and animals following exposure to metallic mercury, methylmercury, or inorganic salts of mercury (ATSDR 1999). Neurological and behavioral disorders (including hand tremors, emotional lability, and performance deficits in tests of cognitive and motor function) have been observed in humans following inhalation of metallic mercury vapor, ingestion or dermal application of medicinal products containing inorganic mercurous salts, and ingestion of seafood contaminated with methylmercury. A single case study of lethal ingestion of mercuric chloride reported neurological symptoms and brain lesions. Animal studies have demonstrated changes in neurobehavioral function, morphology of neurological tissues, and brain neurochemistry following inhalation exposure to metallic mercury or oral exposure to methylmercury. Data for neurological effects of inorganic mercuric mercury salts are limited, and whether associated with oral dosing is uncertain. Effects on neurological development ranging from delays in motor and verbal development to severe brain damage have been observed in children of human mothers orally exposed to organic forms of mercury, including methylmercury (ATSDR 1999). Animal studies provide confirmatory evidence that neurological development of the fetus can be impaired by inhalation exposure of the dams to metallic mercury or oral exposure to methylmercury (ATSDR 1999). Effects on neurological development appear to occur at much lower doses of methylmercury than those producing other effects discussed below (ATSDR 1999). Neurological effects may be the most sensitive effects of inhalation exposure to metallic mercury (ATSDR 1999).

The kidney is another major site of mercury toxicity. Degeneration or necrosis of the proximal convoluted tubules has been observed in humans and animals exposed to metallic mercury, inorganic mercury, or methylmercury (ATSDR 1999). Renal damage is a sensitive effect, however, only for inorganic mercury. In the absence of renal tubular degeneration, exposure to inorganic mercury has been associated in several human cases and certain genetically disposed animals (New Zealand rabbits, Brown Norway rats, and certain strains of mice) with a toxic glomerular response (proteinuria, deposition of immune material in the renal mesangium and glomerular blood vessels, and minimal glomerular cell hyperplasia) that is thought to involve mercury-induced autoimmunity through a stimulation of the humoral and cellular immune systems and systemic autoimmunity (ATSDR 1999; Hultman and Enestrom 1992; Hultman et al. 1994; IRIS 2004). Studies demonstrating an association of this type of autoimmune response with exposure to methylmercury were not located (ATSDR 1999).

Immunosuppressive effects have also been associated with mercury exposure including decreased T-cell reactivity and decreased B cell levels in peripheral blood of mercury-exposed humans, increased susceptibility of mercury-exposed animals to infectious agents, and decreased natural killer cell activity in the spleen and blood of methylmercury-exposed rats (ATSDR 1999; Hultman and Enestrom 1992; Ilback 1991; Ilback et al. 1991).

Effects on male and female reproductive organs or functions associated with mercury exposure include decreased sperm motility in male monkeys orally exposed to methylmercury, decreased spermatogenesis and degeneration of seminiferous tubules in male mice after prolonged oral exposure to methylmercury, impaired spermatogenesis and infertility in male rats and mice following parenteral administration of methylmercury, and increased abortions, increased resorptions, or decreased implantations in female monkeys, guinea pigs, and mice orally exposed to methylmercury (ATSDR 1999).

## C.3 Mechanisms of Action

The high-affinity binding activity of divalent mercuric ion to thiol compounds or sulfhydryl groups of proteins is thought to be a central molecular mode involved in the various toxic actions of inorganic mercury and methylmercury (see ATSDR 1999 for review). The greater potency of methylmercury in producing toxic effects, relative to mercuric salts, is thought to be due to differences in dispositional processes, including gastrointestinal absorption and hepato-biliary recycling, leading to longer retention times and higher doses of the mercuric ion at sites of toxicity.

Mercury-induced damage to neurological or renal tissues has been postulated to involve oxidative stress damage from mercury-induced depletion of reduced glutathione levels, depolarization of mitochondrial inner membranes leading to hydrogen peroxide formation, and depleted levels of reduced pyridine nucleotides (ATSDR 1999). It has been further postulated that neurons are particularly sensitive to mercury because of their low endogenous glutathione content or their inefficient glutathione reduction activity (ATSDR 1999).

Postulates regarding methylmercury’s mechanism of action on the developing nervous system include inhibitory effects of methylmercury on mitosis through impairment of microtubule assembly, methylmercury and inorganic mercury inhibition of enzymes such as protein kinase C, and inhibition of transport mechanisms in developing brain cells (ATSDR 1999).

Molecular and cellular events underlying the immunosuppressive effects of mercury such as increased susceptibility to infectious agents are unclear, but Shenker et al. (1993) showed that methylmercury or mercuric chloride inhibited the mitogenic responses of cultured human T or B cells at concentrations that were about 10-fold lower than those that caused cytotoxicity, and that methylmercury was more potent than mercuric chloride. These authors postulated that immunosuppression involves inhibition by mercury of early stages in the response of these cells to mitogens. The genetically-controlled autoimmunity response to mercury that leads to glomerulonephropathy has been proposed to involve mercury disruption of the balance of helper and suppressor cells within the immunoregulatory network, but the molecular and cellular events that lead to glomerular immune-complex deposits have not been elucidated (ATSDR 1999). Hultman et al. (1994) showed that, in a genetically susceptible mouse strain, prolonged exposure to inorganic mercury caused glomerular immune-complex deposits as well as stimulation of humoral immunity (increased levels of IgM and IgG1), cellular immunity (increased expression of class II molecules and increased mitogen-induced proliferation of T and B cells), and systemic autoimmunity (increased autoantibodies against the nucleolus).

## C.4 Health Guidelines

Data were inadequate for derivation of acute- or intermediate-duration inhalation MRLs for metallic mercury, or for any duration inhalation MRL for inorganic mercury or for methylmercury (ATSDR 1999).

ATSDR (1999) derived a chronic inhalation MRL for metallic mercury vapor of 2×10^−4^ mg/m^3^ based on a LOAEL in occupationally exposed humans of 0.026 mg/m^3^ for neurological effects (equivalent continuous exposure concentration =0.0062 mg/m^3^, after adjusting for 8/24 hours/day and 5 days/week). An uncertainty factor of 30 (10 for human variability and 3 for minimal-effect LOAEL) was used.

ATSDR (1999) did not derive oral MRLs for metallic mercury due to the lack of data. Oral exposure to metallic mercury is expected to present little health risk, because it is so poorly absorbed through the health gastrointestinal tract.

ATSDR (1999) derived an acute-duration oral MRL for inorganic mercury of 0.007 mg Hg/kg/day, based on a NOAEL of 0.93 mg Hg/kg/day (5 days/week) for renal effects in rats administered mercuric chloride for 2 weeks. The NOAEL dose was duration-adjusted and divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). The LOAEL was 1.9 mg/kg/day, 5 days/week.

ATSDR (1999) derived an intermediate-duration oral MRL for inorganic mercury of 0.002 mg Hg/kg/day, based on a NOAEL of 0.23 mg Hg/kg/day for renal effects in rats administered mercuric chloride days/week for 6 months.

ATSDR did not derive a chronic oral MRL for inorganic mercury due to inadequate data.

ATSDR (1999) did not derive acute- or intermediate-duration oral MRLs for methylmercury due to the absence of data or the lack of sufficient information regarding exposure levels associated with observed effects.

ATSDR (1999) derived a chronic oral MRL of 3×10^−4^ mg Hg/kg/day for methylmercury based on observations of no adverse effects in a 66-month evaluation of neurobehavioral development in children who were conceived, born, and resided on the Seychelles Islands and were members of an isolated population that consumed a high quantity and variety of ocean fish containing methylmercury. A NOAEL for methylmercury of 0.0013 mg Hg/kg/day was calculated based on an average level of mercury in maternal hair, 15.3 ppm, from a group (n=95) of the most highly exposed mothers. The NOAEL was divided by a factor of 4.5 to arrive at the MRL. The factor of 4.5 was the sum of an uncertainty factor of 3 (1.5 to address variability in hair-to-blood ratios among women and fetuses in the U.S. population plus 1.5 to address any additional sources of human variability in response to methylmercury) and a modifying factor of 1.5 to address uncertainty regarding the sensitivity of the neurobehavioral tests used in the available report of the Seychelles Islands cohort study.

EPA (IRIS 2004) developed an inhalation RfC of 3×10^−4^ mg/m^3^ for metallic mercury based on a LOAEL of 0.025 mg/m^3^ for 8-hour occupational exposure (converted to LOAEL of 0.009 mg/m^3^ for continuous exposure), and using and uncertainty factor of 30 (10 for human variability and the use of a LOAEL, and 3 for database deficiencies, particularly the lack of developmental and reproductive studies). Inhalation RfCs have not been developed by EPA for inorganic mercury (mercuric chloride) or for methylmercury.

EPA (IRIS 2004) has not developed a chronic oral RfD for metallic mercury.

EPA (IRIS 2004) derived a chronic oral RfD for inorganic mercury (mercuric chloride) of 3×10^−4^ mg Hg/kg/day, based on a LOAELs for autoimmune effects (mercuric mercury induced autoimmune glomerulonephritis) in rat subchronic oral and subcutaneous studies, and back-calculated from a drinking water equivalent level of 0.010 mg/L recommended by a panel of mercury experts, following intensive review and workshop discussions of the entire inorganic mercury database, including the rat LOAELs and limited human tissue data. Data from Brown Norway rats were chosen because this strain is considered a good surrogate for mercury-induced kidney damage in sensitive humans. An uncertainty factor of 1,000 was applied in this derivation (10 for extrapolation from a LOAEL to a NOAEL, 10 for the use of subchronic studies, and a combined 10 for interspecies and intraspecies extrapolation).

EPA (IRIS 2004) derived a chronic oral RfD of 1×10^−4^ mg/kg/day for methylmercury based on an estimated NOAEL of 0.857–1.472 μg/kg/day (maternal intake of methylmercury during pregnancy based on estimated NOAEL cord blood range of 46–79 ppb) for neuropsychological effects in the offspring at 7 years of age in a longitudinal developmental study of about 900 mother-infant pairs from a fish-eating population in the Faroe Islands (Grandjean et al. 1997). The NOAEL was estimated by a benchmark dose approach as the 95% lower confidence limit for a daily dietary intake associated with 5% incidence for the above neurological effects. It is supported by similar studies of mother-infant pairs in the Seychelles islands and in New Zealand. The NOAEL was divided by an uncertainty factor of 10 to derive the RfD (3 for human variability and uncertainty in estimating an ingested mercury dose from cord-blood mercury data and 3 for human variability and uncertainty in pharmacodynamics).

EPA (IRIS 2004) classified metallic mercury in Group D (not classifiable as to human carcinogenicity) based on inadequate human and animal data, and limited and equivocal findings from genotoxicity tests.

EPA (IRIS 2004) classified inorganic mercury (mercuric chloride) in Group C (possible human carcinogen) based on the absence of data in humans and on limited evidence of carcinogenicity in rats and mice. The evidence in animals was considered limited because: the relevance of the observed forestomach papillomas in rats in one oral study of mercuric chloride is of questionable relevance to humans because there was no evidence of progression to malignancy; the relevance of an increase in thyroid tumors in male rats in the same study also is questionable because these tumors are generally considered to be secondary to hyperplasia; the doses in this study exceeded the maximum threshold dose (MTD) for male rats; and evidence for renal adenomas and adenocarcinomas in male mice in another oral study of mercuric chloride study was equivocal. Genotoxicity assays of mercuric chloride gave mixed results.

EPA (IRIS 2004) classified methylmercury in Group C (possible human carcinogen) based on inadequate data in humans and limited evidence of carcinogenicity in animals. The animal evidence was judged to be limited because: methylmercury-induced tumors (kidney tumors, from oral exposure) were observed at a single site, in a single species and in a single sex; the tumors were observed only in the presence of profound nephrotoxicity; several nonpositive oral cancer bioassays have also been reported; and the evidence that methylmercury is genotoxic is equivocal. Quantitative estimates of cancer risk from oral exposure were not derived based on evidence that methylmercury exerts its carcinogenic effects only at high doses above a maximum tolerated dose and that systemic noncancer effects on the nervous system would be seen at methylmercury exposure levels lower that those required to produce kidney damage and subsequent kidney tumor development. Pertinent inhalation data were not available.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

An intermediate oral MRL is available for inorganic (mercuric) mercury, based on renal effects, and can be used for the screening level assessment recommended in this interaction profile.

A chronic oral MRL is available for methylmercury, based on neurological effects, the primary endpoint of concern for this mixture.

TTDs for oral exposure to methylmercury were derived previously for endpoints relevant to a different mixture that is the subject of other interaction profiles. The previously derived TTDs are retained in this appendix only for the sake of completeness. The methods used for deriving TTDs are described in ATSDR (2001a). The derivations are based on data provided in ATSDR (1999), and in particular, the oral Levels of Significant Exposure (LSE) table. Where the data were inadequate to derive a chronic oral TTD for a given endpoint, the chronic oral MRL is recommended as a conservative alternative that is protective of human health.

### Renal Effects (Inorganic Mercury)

ATSDR (1999) derived an intermediate oral MRL for inorganic (mercuric) mercury was based on a NOAEL of 0.23 mg Hg/kg/day for renal effects in rats administered mercuric chloride days/week for 6 months. The duration of the study was viewed as ideal, because it was long enough to detect long-term effects and short enough not to mix them with renal effects of aging rats. This MRL is suitable for the screening level assessment for intermediate to chronic oral exposure recommended in this interaction profile.

### Immunological Effects (Methylmercury)

Although immunosuppression is a known toxic endpoint for mercury, quantitative dose-response information for methylmercury is limited. Ilback (1991) reported a LOAEL of 0.5 mg Hg/kg/day for decreased thymus weight and cell number and reduced natural killer cell activity in mice fed methylmercury in the diet for 12 weeks. No other data were located regarding oral exposure to organic mercury (ATSDR 1999). Because a free-standing intermediate LOAEL with no supporting data is not a suitable basis for TTD derivation, the chronic oral MRL of 3×10^−4^ mg Hg/kg/day is adopted as TTD_IMMUNO_ for methylmercury. Using the chronic oral MRL as the TTD is protective of human health.

### Neurological Effects (Methylmercury)

The neurological effects of methylmercury are well documented in humans and animals, and are the critical effects of methylmercury (ATSDR 1999). The chronic oral MRL of 3×10^−4^ mg Hg/kg/day developed by ATSDR (1999) is based on neurological effects in the population of particular concern for this mixture (developing children). Therefore, a TTD is not needed for this endpoint.

### Reproductive Effects (Methylmercury)

Studies of the reproductive effects of methylmercury are described in ATSDR (1999). The lowest reliable LOAEL for reproductive effects was 0.06 mg Hg/kg/day, which produced an increased rate of reproductive failure due to decreased conceptions and increased early abortions and stillbirths in female monkeys treated with methylmercury for 4 months (Burbacher et al. 1988). The NOAEL in this study was 0.04 mg Hg/kg/day. Although there was a report of sperm effects in male monkeys exposed to 0.025 or 0.035 mg Hg/kg/day by gavage for 20 weeks (Mohamed et al. 1987), this study was not considered reliable by ATSDR (1999). Chronic studies in rodents reported testicular lesions (tubular atrophy) and decreased spermatogenesis at approximately 0.7 mg Hg/kg/day, with NOAEL values of roughly 0.1 mg Hg/kg/day in both sexes (Hirano et al. 1986; Mitsumori et al. 1990; Verschuuren et al. 1976). The 4-month monkey study is a suitable basis for a TTD. Application of an uncertainty factor of 100 (10 for extrapolation from monkeys to humans and 10 to protect sensitive individuals) to the NOAEL of 0.04 mg Hg/kg/day yields a TTD_repro_ of 4×10^−4^ mg Hg/kg/day, which is only slightly higher than the chronic oral MRL of 3×10^−4^ mg Hg/kg/day.

### Summary (TTDs for inorganic mercury)

MRL_RENAL_ = 0.002 mg Hg/kg/day

### Summary (TTDs for methylmercury)

- MRL_NEURO_ = 3×10^−4^ mg Hg/kg/day (3×10^−4^ mg/kg/day)
- TTD_IMMUNO_ = 3×10^−4^ mg Hg/kg/day (3×10^−4^ mg/kg/day)
- TTD_REPRO_ = 4×10^−4^ mg Hg/kg/day (4×10^−4^ mg/kg/day)

For methylmercury, only the MRL_NEURO_ is used in this interaction profile. As explained previously, the other TTDs were derived for endpoints of concern for joint toxic action of a different mixture, which is the subject of a separate interaction profile.

## C.6 References

ATSDR. 1999. Toxicological profile for mercury. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry
ATSDR. 2001a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Burbacher TM, Mohamed MK, Mottett NK. 1988. Methylmercury effects on reproduction and offspring size at birth. Reprod Toxicol 1(4):267–278.
Grandjean P, Weihe P, White RF, 1997. Cognitive deficit in 7-year-old children with prenatal exposure to methylmercury. Neurotoxicol Teratol 19:417–428.9392777
Hirano M, Mitsumori K, Maita K, 1986. Further carcinogenicity study on methylmercury chloride in ICR mice. Jpn J Vet Sci 48(1):127–135.
Hultman P, Enestrom S. 1992. Dose-response studies in murine mercury-induced autoimmunity and immune-complex disease. Toxicol Appl Pharmacol 113:199–208.1532866
Hultman P, Johansson U, Turley SJ, 1994. Adverse immunological effects and autoimmunity induced by dental amalgam and alloy in mice. FASEB J 8:1183–1190.7958626
Ilback N-G. 1991. Effects of methyl mercury exposure on spleen and blood natural killer (NK) cell activity in the mouse. Toxicology 67:117–124.2017762
Ilback N-G, Sunderberg J, Oskarsson A. 1991. Methyl mercury exposure via placenta and milk impairs natural killer (NK) cell function in newborn rats. Toxicol Lett 58:149–158.1949074
IRIS. 2004. Integrated Risk Information Systems. U.S. Environmental Protection Agency. http://www.epa.gov.iris. January 2004.
Mitsumori K, Hirano M, Ueda H, 1990. Chronic toxicity and carcinogenicity of methylmercury chloride in B6C3F1 mice. Fund Appl Toxicol 14:179–190.
Mohamed M, Burbacher T, Mottett N. 1987. Effect of methyl mercury on testicular functions in Macaca fascicularis monkeys. Pharmacol Toxicol 60(1):29–36.3562387
Nublien F, Feicht EA, Schulte-Hostede S, 1995. Exposure analysis of the inhabitants living in the neighborhood of a mercury-contaminated industrial site. Chemosphere 30(12):2241–2248.7620851
Shenker BJ, Berthold P, Rooney C, 1993. Immunotoxic effects of mercury compounds on human lymphocytes on monocytes. III. Alterations in B-cell function and viability. Immunopharmacol Immunotoxicol 15(1):87–112.8450183
Verschuuren HG, Kroes R, Den Tonkelaar EM, 1976. Toxicity of methylmercury chloride in rats. III. Long-term toxicity study. Toxicology 6:107–123.941159