# Appendix A Background Information for Chlorpyrifos

Chlorpyrifos is an organophosphorus insecticide. It belongs to the phosphorothioate (also called phosphorothionate) group, composed of organophosphorus compounds that contain the P=S substructure. Other organophosphorus insecticides in this group include diazinon, methyl parathion, parathion, fenthion, and fenitrothion. These compounds require metabolic activation to their oxon analogs (compounds in which the =S is replaced by =O) for anticholinesterase activity. The structures of chlorpyrifos and its toxic metabolite, chlorpyrifos oxon, are provided in Appendix D.

As of 2000, chlorpyrifos was one of the most widely used organophosphorus insecticides in the United States, for both agricultural and residential purposes. Registered uses included food crops, turf and ornamental plants, indoor pest control (including crack and crevice treatment), termite control, mosquito control, and pet collars. It was registered for use in a wide variety of buildings, including residential, commercial, schools, daycare centers, restaurants, hospitals, hotels, and food manufacturing plants (EPA 2000c). Many uses of chlorpyrifos are being phased out (see Section A.4).

A study of urinary pesticide metabolites during the third trimester in 386 pregnant women from East Harlem indicated that exposure to chlorpyrifos was prevalent (42% of the women had detectable levels of the chlorpyrifos metabolite), was higher than the median in NHANES III, did not show seasonal variation, and did not change during the time period of the study (1998–2001) (Berkowitz et al. 2003). The exposure of these women was thought to be primarily indoor, due to household use and pesticide exterminator application, and also dietary. A study of nine homes and 18 adult residents, 2/home, conducted in the Lower Rio Grande Valley concluded that indoor dust and air were the primary exposure media for the residents of those households, based on monitoring of those media, as well as outdoor soil and air, food, and a characteristic urinary metabolite of chlorpyrifos (as a biomarker of exposure) (Buckley et al. 1997).

## A.1 Toxicokinetics

Chlorpyrifos is known to be absorbed through the respiratory tract in humans and animals, but quantitative estimates were not available (ATSDR 1997; FAO/WHO 1999).

Chlorpyrifos is readily absorbed from the gastrointestinal tract. Based on the percent of administered dose excreted in the urine, absorption of chlorpyrifos in humans was about 70% in a single-dose oral study (Nolan et al. 1984), and in rats ranged from 84–90% in single-dose gavage studies (ATSDR 1997; EPA 2000b).

Dermal absorption of chlorpyrifos (in dipropylene glycol methyl ether) in humans was about 1.3% of the administered dose within 48 hours (Nolan et al. 1984). Dermal absorption in animals was much higher, but results were confounded by dermal irritation, and even blistering, which compromised the integrity of the skin.

The main features of chlorpyrifos metabolism (ATSDR 1997; Buratti et al. 2003; FAO/WHO 1999; Tang et al. 2001) are:

- activation of chlorpyrifos by cytochrome P450 oxidative desulfuration of the P=S moiety to P=O, resulting in the toxic intermediate, chlorpyrifos oxon;
- detoxification by cytochrome P450 dearylation of chlorpyrifos, resulting in 3,5,6-trichloro-2-pyridinol, and diethyl thiophosphate;
- detoxification by A-esterases (including paraoxonases) that hydrolyze the phosphate ester bonds of chlorpyrifos and chlorpyrifos oxon to form 3,5,6-trichloro-2-pyridinol, and also diethyl thiophosphate (from chlorpyrifos), or diethylphosphate (from chlorpyrifos oxon); and
- formation of glucuronide and sulfate conjugates of 3,5,6-trichloro-2-pyridinol (TCP).

Metabolic activation occurs predominantly in the liver. Detoxification occurs predominantly in liver and plasma (ATSDR 1997; FAO/WHO 1999).

Metabolism of chlorpyrifos is rapid and extensive; the parent compound and the oxon are not detected or are found only in trace concentrations in blood or urine, except following very high exposures. The metabolite TCP is the principal form found in the circulation (ATSDR 1997; FAO/WHO 1999). The elimination half-life for this metabolite in humans following oral or dermal exposure was approximately 27 hours (Nolan et al. 1984). Chlorpyrifos metabolites are excreted primarily in the urine (ATSDR 1997; FAO/WHO 1999).

In humans, the cytochrome P450 isozymes that activate chlorpyrifos are CYP1A2 and CYP2B6 at low chlorpyrifos concentrations (environmentally relevant) (Buratti et al. 2003), and CYP3A4 and also CYP2B6 at higher concentrations (Burati et al. 2003; Tang et al. 2001). Isozymes involved in dearylation of chlorpyrifos are reported to be CYP2C19 and CYP3A4 (Tang et al. 2001).

## A.2 Health Effects

The principal toxic effect of chlorpyrifos in humans, experimental animals, and insects is acetylcholinesterase inhibition. Acetylcholine is a neurotransmitter in the central and peripheral neurons. Inhibition of acetylcholinesterase, the enzyme that breaks down and terminates the action of acetylcholine, results in the accumulation of acetylcholine at acetylcholine receptors leading to continued stimulation.

In humans and experimental animals, the accumulation of acetylcholine results in cholinergic responses in the peripheral (muscarinic and nicotinic) and central nervous system and neuromuscular junctions. These cholinergic responses, seen in severe acetylcholinesterase inhibition, include excessive glandular secretions (salivation, lacrimation, rhinitis), miosis, bronchoconstriction, vasodilation, hypotension, diarrhea, nausea, vomiting, urinary incontinence, and bradycardia associated with muscarinic receptor stimulation. Tachycardia, mydriasis (dilation of the pupil), muscle fasciculations, cramping, twitching, muscle weakness, muscle paralysis, and hypertension are associated with nicotinic receptor stimulation. Central nervous system toxicity includes respiratory depression, anxiety, insomnia, headache, apathy, drowsiness, dizziness, loss of concentration, confusion, tremors, convulsions, and coma. These effects usually appear within a few minutes to 24 hours after exposure, depending on the extent and route of exposure. In nonfatal exposures, the effects are usually transient, with rapid and complete recovery following cessation of exposure. Recovery from chlorpyrifos poisoning results from increased availability of active acetylcholinesterase either from synthesis of new enzyme, the spontaneous hydrolysis of the enzyme-phosphate ester complex, or treatment with atropine, a competitive antagonist of acetylcholine at muscarinic and central nervous system receptors, and with pralidoxime (2-PAM), a drug that regenerates inhibited acetylcholinesterase enzyme by displacing the diethylphosphoester bond that chlorpyrifos oxon forms at the active site (Aaron and Howland 1998; ATSDR 1997).

Transient, delayed polyneuropathy has been reported in humans in case reports of acute- or intermediate-duration exposure to chlorpyrifos; these reports did not adequately characterize exposure (ATSDR 1997; FAO/WHO 1999). Chlorpyrifos has been tested for organophosphate-induced delayed neurotoxicity in chickens; results were negative in these oral studies except at doses 4–6 times the LD_50_, which required aggressive antidotal treatment (ATSDR 1997).

Acetylcholinesterase activity is also present in erythrocytes where it is known as erythrocyte acetylcholinesterase. Both forms of acetylcholinesterase are produced by the same gene and are kinetically identical. In in vitro assays, erythrocyte and neural acetylcholinesterase are inhibited to roughly the same extent by exposure to diazinon and many other organophosphorus compounds with insecticidal activity; measurement of erythrocyte acetylcholinesterase can be used as a surrogate indicator of the extent of inhibition of neural acetylcholinesterase (ATSDR 1997).

A cholinesterase capable of hydrolyzing acetylcholine and butrylcholine is produced by the liver and circulates in the blood. This enzyme, referred to as serum cholinesterase, plasma cholinesterase, pseudocholinesterase, or butyrylcholinesterase, is also inhibited by chlorpyrifos and is often used as a marker for exposure (ATSDR 1997). This enzyme is present in some nonneural cells in the central and peripheral nervous systems as well as in plasma and serum, the liver, and other organs. Its physiologic function is not known, but is hypothesized to be the hydrolysis of esters ingested from plants (Lefkowitz et al. 1996). Plasma cholinesterases are also inhibited by organophosphate compounds through irreversible binding; this binding can act as a detoxification mechanism as it affords some protection to acetylcholinesterase in the nervous system (Parkinson 1996; Taylor 1996). In general, this enzyme is inhibited at lower levels of organophosphate exposure than required to inhibit neural or erythrocyte acetylcholinesterase. For chlorpyrifos, plasma cholinesterase is inhibited earlier in the time course of events following a single dose or exposure, followed by acetylcholinesterase (ATSDR 1997).

Developing children (including infants and fetuses) are predicted to be more sensitive than adults to the neurotoxicity of chlorpyrifos, based on studies in animals (ATSDR 1997; EPA 2000b).

Chlorpyrifos was evaluated for carcinogenicity in 2-year feeding studies in rats, mice, and dogs; results were negative (ATSDR 1997; EPA 2000b).

## A.3 Mechanisms of Action

Chlorpyrifos and chlorpyrifos oxon inhibit acetylcholinesterase by reacting with the active site to form a stable dialkylphosphorylated enzyme that cannot hydrolyze acetylcholine. Chlorpyrifos oxon, the active metabolic intermediate of chlorpyrifos, is much more potent than chlorpyrifos in inhibiting acetylcholinesterase (ATSDR 1997; FAO/WHO 1999).

## A.4 Health Guidelines

ATSDR (1997) did not derive inhalation MRLs for chlorpyrifos because of the lack of suitable information for any exposure duration.

ATSDR (1997) derived acute and intermediate oral MRLs of 0.003 mg/kg/day for chlorpyrifos based on a no-observed-adverse-effect level (NOAEL) of 0.03 mg/kg/day for plasma cholinesterase inhibition in adult male volunteers who ingested chlorpyrifos by capsule for 20 days (Coulston et al. 1972). An uncertainty factor of 10 was used for human variability. The lowest-observed-adverse-effect level (LOAEL) (65% mean decrease in plasma cholinesterase; and symptoms possibly associated with exposure in one of four volunteers) was 0.1 mg/kg/day for 9 days.

ATSDR (1997) derived a chronic oral MRL of 0.001 mg/kg/day based on a NOAEL of 0.1 mg/kg/day for plasma, erythrocyte, and brain cholinesterase inhibition in rats fed chlorpyrifos in their diet for 2 years. Plasma and erythrocyte cholinesterase were inhibited at 1 and 3 mg/kg/day, and brain cholinesterase was inhibited at 3 mg/kg/day. An uncertainty factor of 100 was used to extrapolate from animals to humans and to account for human variability.

EPA (IRIS 2004) derived a chronic RfD for chlorpyrifos based on the human study that ATSDR (1997) also used for oral MRL derivation (referenced as Dow Chemical Company 1972 by IRIS 2004). EPA applied an uncertainty factor of 10 to the no-observed-effect level (NOEL) of 0.03 mg/kg/day, resulting in a chronic oral RfD of 0.003 mg/kg/day. This RfD was verified in 1986.

More recently, the EPA (2000c) Office of Pesticide Programs (OPP) reevaluated the use of the human data as the basis for its acute and chronic RfDs because of a joint Science Advisory Panel/Science Advisory Board meeting in December 1998 that discussed issues regarding the scientific and ethical concerns for human toxicity testing. There was a concern that a regulatory decision cannot be based on a human study until a formal decision has been made concerning the ethical aspects of this use (EPA 2000c). Since the ethics decision had not yet been made, and as part of the reevaluations conducted for reregistration and under the FQPA, the EPA (2000c) OPP has reevaluated the human and animal data, concluding that the human data provided useful information that can be used as supportive data, and derived new RfDs based on the animal data. An acute RfD of 0.005 mg/kg/day, based on plasma cholinesterase inhibition in an acute oral study in rats, and a chronic RfD of 3×10^−4^ mg/kg/day, based on the weight of evidence for plasma and erythrocyte cholinesterase inhibition from five oral studies in dogs and rats, were derived. Although not on in the Integrated Risk Information System (IRIS), these derivations include a consideration of toxicological and mechanistic data that have become available since the RfD on IRIS was derived (by OPP). These newer RfDs have been subjected to extensive review, including public comment, and are available online (EPA 2000c). The FQPA safety factor of 10 (EPA 2003) was applied to these RfDs to estimate population adjusted doses (PADs) for children and females 13–50 when assessing dietary (food + drinking water) exposures, resulting in a acute PAD of 5×10^−4^ mg/kg/day and a chronic PAD of 3×10^−5^ mg/kg/day (EPA 2000c).

In June of 2000, EPA announced an agreement with chlorpyrifos registrants to eliminate certain uses of this pesticide (EPA 2000a, 2002a). Uses on foods frequently eaten by children (apples, grapes, tomatoes), uses by homeowners (except for ant baits in child resistant containers), and uses in settings such as schools and parks where children may be exposed, are being canceled, or phased out, or limited to minimize exposure. Residential uses by licensed applicators are being phased out or limited to lower application concentrations or rates. Reduced application rates for other agricultural uses and golf courses also are being instituted to protect workers and wildlife.

The National Toxicology Program (NTP) (2003) and the International Agency for Research on Cancer (IARC) (2003) do not include chlorpyrifos in their listings. The EPA (2002b) Office of Water classified chlorpyrifos in Cancer Group D (not classifiable as to human carcinogenicity).

## A.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The relevant endpoint for chlorpyrifos in this mixture is neurological. The intermediate oral MRL of 0.003 mg/kg/day for chlorpyrifos is based on neurological effects in humans. Chlorpyrifos is not known to be a cumulative or persistent toxin, so this MRL is appropriate for the screening level assessment of neurological effects of intermediate to chronic oral exposure to chlorpyrifos. Derivation of this MRL was described in the Section A.4.

### Summary (TTD for Chlorpyrifos)

MRL_NEURO_ = 0.003 mg/kg/day

## A.6 References

Aaron CK, Howland MA. 1998. Insecticides: Organophosphates and carbamates. In: Goldfrank LR, Flomenbaum NE, Lewin NA, , eds. Goldfrank’s toxicological emergencies. Stamford, CT: Appleton & Lange, 1429–1449.
ATSDR. 1997. Toxicological profile for chlorpyrifos. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Berkowitz GS, Obel J, Deych E, 2003. Exposure to indoor pesticides during pregnancy in a multiethnic, urban cohort. Environ Health Perspect 111(1):79–84.12515682
Buckley TJ, Liddle J, Ashley DL, 1997. Environmental and biomarker measurements in nine homes in the lower Rio Grande valley: Multimedia results for pesticides, metals, PAHs, and VOCs. Environ Int 23(5):705–732.
Buratti FM, Volpe MT, Meneguz A, 2003. CYP-specific bioactivation of four organophosphorothioate pesticides by human liver microsomes. Toxicol Appl Pharmacol 186(3):143–154 12620367
Coulston F, Goldberg L, Abraham R, 1972. Final report on safety evaluation and metabolic studies on Dow co. 179(IN151). Inst Exp Pathol Toxicol, Albany Medical College. (As cited in ATSDR 1997.)
EPA. 2000a. Chlorpyrifos revised risk assessment and agreement with registrants. U.S. Environmental Protection Agency. Prevention, pesticides and toxic substances (7506C). http://www.epa.gov/pesticides/op/chlorpyrifos/agreement.pdf. June 2000.
EPA. 2000b. Toxicology chapter for chlorpyrifos. Washington, DC: U.S. Environmental Protections Agency. Office of Prevention, pesticides and toxic substances. http://www.epa.gov/oppsrrd1/op/chlorpyrifos/rev_tox.pdf. April 18, 2000.
EPA. 2000c. Human health risk assessment. Chlorpyrifos. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/oppsrrd1/op/chlorpyrifos/hedrra. June 8, 2000.
EPA. 2002a. Pesticides: Organophosphates. Chlorpyrifos facts. Washington, DC: U.S. Environmental Protections Agency. http://www.epa.gov/oppsrrd1/REDs/factsheets/chlorpyrifos_fs.htm.
EPA. 2000b. Toxicology chapter for chlorpyrifos. Washington, DC: U.S. Environmental Protections Agency. Office of Prevention, Pesticides and Toxic Substances. http://www.epa.gov/oppsrrd1/op/chlorpyrifos/rev_tox.pdf. April 18, 2000.
EPA. 2003. Pesticides. Regulating pesticides. The Food Quality Protection Act (FQPA). http://www.epa.gov/oppfead1/fqpa/backgrnd.htm.
FAO/WHO. 1999. Pesticide residues in food. Toxicological evaluations. International Programme on Chemical Safety. Food and Agriculture Organization & World Health Organization, 1–61. http://www.inchem.org/documents/jmpr/jmpmono/v99pr03.htm.
IARC. 2003. Overall evaluations of carcinogenicity to humans: As evaluated in IARC Monographs volumes 1–82 (a total of 885 agents, mixtures and exposures). International Agency for Research on Cancer. http://193.51.164.11/moneeval/crthall.html. January 2004.
IRIS. 2004. Integrated Risk Information Systems. U.S. Environmental Protection Agency. http://www.epa.gov.iris. January 2004.
Lefkowitz RJ, Hoffman BB, Taylor P. 1996. Neurotransmission: The autonomic and somatic motor nervous systems. In: Goodman LS, Gilman A, Hardman JG, , eds., Goodman & Gilman's the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 105–139.
Nolan RJ, Rick DL, Freshour NL. 1984. Chlorpyrifos: Pharmacokinetic in human volunteers. Toxicol Appl Pharmacol 73(1):8–15.6200956
NTP. 2003. 10th report on carcinogens. U.S. Department of Health and Human Services. National Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Parkinson A. 1996. Biotransformation of xenobiotics. In: Klassen CD, ed. Cassarett and Doull’s Toxicology Program. http://ehp.niehs.nih.gov/roc/toc10.htm.
Tang J, Cao Y, Rose RL, 2001. Metabolism of chlorpyrifos by human cytochrome P450 isoforms and human, mouse, and rat liver microsomes. Drug Metab Dispos 29(9):1201–1204.11502728
Taylor P. 1996. Anticholinesterase agents. In: Goodman LS, Gilman A, Hardman JG, , eds. Goodmand & Gilman’s the pharmacological basis of therapeutics. New York, NY: McGraw-Hill: Health Professions Division, 161–176.