# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienists
ALA: aminolevulinic acid
ALAD: aminolevulinic acid dehydratase
ALAS: delta-aminolevulinic acid synthetase
ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
BUN: blood urea nitrogen
CAS: Chemical Abstracts Service
CDC: Centers for Disease Control and Prevention
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
Cpf: chlorpyrifos
DT: Division of Toxicology
EPA: Environmental Protection Agency
FAO: Food and Agriculture Organization
FQPA: Food Quality Protection Act
GABA: gamma-aminobutyric acid
Hg: mercury
HI: hazard index
IARC: International Agency for Research on Cancer
IEUBK: Integrated Exposure Uptake Biokinetic
ip: intraperitoneal
IPCS: International Programme on Chemical Safety
IRIS: Integrated Risk Information System
iv: intravenous
kg: kilogram
L: liter
LC_50_: median lethal concentration (produces desired effect in 50% of the population)
LD_50_: median lethal dose (produces desired effect in 50% of the population)
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
MeHg: methylmercury
mg: milligram
MRL: Minimal Risk Level
MTD: maximum threshold dose
NHANES: National Health and Nutrition Examination Survey
nM: nanomole
NOAEL: no-observed-adverse-effect level
NOEL: no-observed-effect level
NTP: National Toxicology Program
OP: organophosphorus compound
OPP: Office of Pesticide Programs
PAD: population adjusted dose
2-PAM: pralidoxime
PFC: plaque-forming cells
Pb: lead
pbB: blood lead concentration
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic/pharmacodynamic
ppb: parts per billion
ppm: parts per million
RfC: reference concentration
RfD: reference dose
sc: subcutaneous
TCP: 3,5,6-trichloro-2-pyridinol
TTD: target-organ toxicity dose
μg: microgram
μmole: micromole
U.S.: United States
VOC: volatile organic compound
WHO: World Health Organization
WOE: weight-of-evidence
ZPP: zinc protoporphyrin
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to