# ACKNOWLEDGMENT

The Agency for Toxic Substances and Disease Registry (ATSDR) wishes to thank the U.S. Environmental Protection Agency (EPA) for its support in the production of this Interaction Profile.