# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

Ah: arylhydrocarbon
AHH: arylhydrocarbon hydroxylase
ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
BROD: benzoxylresorufin-O-deethylase
CDD: chlorinated dibenzo-p-dioxin
CDF: chlorinated dibenzofuran
CI: confidence interval
CYP: cytochrome P450
DNA: deoxyribonucleic acid
DTH: delayed-type hypersensitivity
EGF: epidermal growth factor
EPA: Environmental Protection Agency
EROD: ethoxyresorufin O-deethylase
HCB: hexachlorobenzene
IARC: International Agency Research on Cancer
IRIS: Integrated Risk Information System
kg: kilogram
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
mg: milligram
MRL: Minimal Risk Level
mRNA: messenger ribonucleic acid
NOAEL: no-observed-adverse-effect level
OR: odds ratio
PBB: polybrominated biphenyl
PBPK: physiologically based pharamacokinetic
PCB: polycholrinated biphenyl
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
RfC: Reference Concentration
RfD: Reference Dose
SD: standard deviation
SRBC: sheep red blood cells
T4: thyroxin
TT3: total triiodothyronine
TT4: total thyroxine and free thyroxine
TAO: triacetyloleandomycin
TCDD: 2,3,7,8-tetrachlorodibenzo-p-dioxin
TCDF: tetrachlorodibenzofuran
TCHQ: tetrachlorohydroquinone
TEF: Toxic Equivalency Factor
TEQ: toxic equivalents
TGF: transforming growth factor
TSH: thyroid stimulating hormone
TTD: target-organ toxicity dose
UDP: uridine-5'-diphosphate
UF: uncertainty factor
U.S.: United States
WOE: weight-of-evidence
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to