# SUMMARY

Chlorinated dibenzo-p-dioxins (CDDs), hexachlorobenzene, p,p’-DDE (the predominant metabolite of p,p’-DDT), methylmercury, and polychlorinated biphenyls (PCBs) occur with high frequency in water, sediment, and fish from the North American Great Lakes and occur, to varying degrees, in other dietary components including fish from other parts of the world (e.g., the Baltic Sea), human milk, dairy products, and meat. The purposes of this profile are (1) to evaluate data (if available) on health hazards, and their dose-response relationships, from oral exposure to this five-component mixture, (2) to evaluate data on the joint toxic actions of components of this mixture, and (3) to make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

No studies were located that examined health effects in humans or animals exposed to mixtures exclusively containing CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs, and no physiologically based pharmacokinetic/pharmacodynamic models (PBPK/PD) for this mixture have been developed.

Studies of possible associations between health effects and frequent consumption of Great Lakes and Baltic Sea fish containing the components of this mixture (and other persistent chemicals) were reviewed to determine the degree to which available data may identify pertinent health hazards. Frequent dietary consumption of contaminated Great Lakes fish by child-bearing-aged women has been associated in two prospective epidemiological studies with neurological deficits in their children, but other studies provide no consistent evidence that consumption of Great Lakes fish presents obvious risks for impaired reproduction, impaired immune capabilities, or physical birth defects. Low birth weight was reported in children of mothers who frequently ate Baltic Sea fish, and impaired immunological competence was reported in seals fed Baltic Sea fish, but the data do not clearly demonstrate dose-response relationships.

The weight of evidence for an association between Great Lakes fish consumption and effects on neurological development is greater than that for associations between frequent consumption of contaminated Baltic Sea fish and impaired immune capabilities or low birth weight, but none of the weights are sufficient to establish causal relationships between fish consumption and adverse health effects in humans. PCBs have been proposed as toxicants involved in the possible association between maternal fish consumption and altered childhood neurological development based on statistically significant associations between specific PCB levels in maternal fluids and neurological deficits in children. Other hypotheses, however, have been proposed, including the possible involvement of other persistent chemicals in contaminated fish or synergistic interactions between PCBs and other neurotoxicants in fish.

The concentrations of persistent chemicals in fish are likely to be highly dependent on species and location, and a minium risk level (MRL) for fish consumption based on responses in one population may not be applicable to another population. To facilitate exposure-based assessments of possible health effects associated with oral exposures to mixtures of CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs, available data on the joint toxic action of mixtures of these chemicals were reviewed, and the weights of evidence were assessed concerning the mode of joint toxic action of pairs of the five components. In this analysis, 2,3,7,8-tetrachlorodibenzo-p-dioxin ( 2,3,7,8-TCDD) was taken as a representative of CDDs in accordance with the Toxicity Equivalence Factor (TEF) approach to assessing hazards from mixtures of CDDs. PCB mixtures were assessed as an entity in accordance with ATSDR’s PCB MRLs which are derived for exposure to complex mixtures of PCBs.

The weight-of-evidence analysis indicates that only a limited amount of evidence is available to support the possible existence of greater-than-additive or less-than-additive joint actions of a few pairs of the components: (1) hexachlorobenzene potentiation of 2,3,7,8-TCDD reduction of body and thymus weights; (2) PCB antagonism of TCDD immunotoxicity and TCDD developmental toxicity; and (3) synergism between PCBs and methylmercury in disrupting regulation of brain levels of dopamine that may influence neurological function and development. Confidence in these assessments of deviations from additivity was low. For a few of the remaining pairs, additive joint action at shared targets of toxicity is supported by data, and for the rest, data were not available to characterize the modes of joint toxic action.

Component-based approaches that assume additive joint toxic action are recommended for exposure-based screening assessments of possible noncancer or cancer health hazards from oral exposure to mixtures of CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs, because there are no direct data available to characterize health hazards (and dose-response relationships) from the five-component mixture. The weight-of-evidence analysis indicated that data are inadequate to characterize the modes of joint action of the components, but the additivity assumption appears to be suitable in the interest of protecting public health since the components have several shared toxicity targets.

In making the recommendation, it is acknowledged that results from two epidemiological studies identify altered neurological development as a possible health hazard from frequent consumption of fish contaminated with biopersistent chemicals. However, the results do not establish a causal relationship and are not directly useful for exposure-based assessments of hazards that are specific to a community or an exposure-scenario. The recommended approaches allow assessment of the possibility of altered neurological development as well as other potential health hazards including cancer.

A target-organ toxicity dose (TTDs) modification of the Hazard Index approach is recommended for conducting exposure-based screening assessments of noncancer health hazards. TTDs for several toxicity targets have been derived for each of the components including TTDs for hepatic, endocrine, immunological, neurological, reproductive, and developmental. For a screening assessment of cancer risks from joint toxic action of the mixture, a similar component-based approach is recommended that involves multiplication of intakes of the components by EPA cancer slope factors and summation of the resultant risk estimates. If the screening assessment indicates a potential hazard, further evaluation is needed, using biomedical judgment and community-specific health outcome data, and taking into account community health concerns.