# PEER REVIEW

The following expert panel was assembled to review this document on May 30–31, 2000.

- Vladimir Bencko, M.D., Ph.D.
  Institute of Hygiene and Epidemiology
  Charles University of Prague
  Studnickova 7
  CZ 128 00 Prague 2
  Czech Republic
- Ingvar Eide, Ph.D.
  Statoil Research Centre
  N-7005 Trondheim, Norway
- Henry Gardner, Ph.D.
  3407 Rolling Green Drive
  Ft. Collins, CO 80525
- Peter Grevatt, Ph.D.
  U.S. Environmental Protection Agency
  Office of Solid Waste & Emergency Response
  Washington, DC
- John Groten, Ph.D.
  Department of Explanatory Toxicology
  TNO Nutrition and Food Research Institute
  Zeist, Netherlands
- Richard Hertzberg, Ph.D.
  Waste Management Division
  U.S. Environmental Protection Agency
  Atlanta, GA
- Kannan Krishnan, Ph.D.
  Human Toxicology Research Group
  University of Montreal
  Montreal, PQ, Canada
- Scott Masten, Ph.D.
  Environmental Toxicology Program
  National Institute of Environmental Health Sciences
  Research Triangle Park, NC
- Mark McClanahan, Ph.D.
  Centers for Disease Control and Prevention
  National Center for Environmental Health
  Health Studies Branch
  Atlanta, GA
- Harihara Mehendale, Ph.D.
  Department of Toxicology
  College of Pharmacy
  University of Louisiana
  Monroe, LA
- Joel Pounds, Ph.D.
  Department of Molecular Biosciences
  Pacific Northwest National Laboratory
  Richland, WA
- Jane Ellen Simmons, Ph.D.
  U.S. Environmental Protection Agency
  Research Triangle Park, NC
- Madhusudan Soni, Ph.D.
  Burdock and Associates, Inc.
  Vero Beach, FL
- Els van Vliet, Ph.D.
  Health Council of the Netherlands
  2500 BB Den Haag
  The Netherlands
- Raymond Yang, Ph.D.
  Center for Environmental Toxicology and Technology
  Colorado State University
  Fort Collins, CO

## Technical Reviewer

- Patrick Durkin, Ph.D.
  Syracuse Environmental Research Associates
  Fayetteville, NY

All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.