# Appendix F Chemical Structures of Mixture Components

Chlorinated dibenzo-p-dioxins

Congeners can have chlorine substitutions at positions 1–4 and 6–9.

chemical structures

Hexachlorobenzene

chemical structures

p,p’DDE

chemical structures

Methylmercury

(L indicates a ligand.)

chemical structures

PCBs

Congeners can have chlorine substitutions at positions 2–6 and 2'–6'.

chemical structures