# Appendix E Background Information for PCBs

PCBs were manufactured in the United States between about 1930 and 1977, predominately for use as coolants and lubricants in electrical equipment, such as transformers and capacitors, due to their general inertness (they resist degradation by acids or alkali) and heat stability (ATSDR 2000). The manufacture of PCBs in the United States was stopped due to the evidence that they accumulate and persist in the environment and can cause toxic effects. Due to their biostability and lipophilicity, PCBs accumulate and concentrate in food chains; PCB concentrations in fatty tissue increase with increasing order of species in a food chain. There are 209 possible congeners of chlorinated biphenyls. PCBs were manufactured as complex mixtures of chlorinated biphenyls that varied in the degree of chlorination. For example, the commercial product Aroclor 1242, was a mixture of mono- through hepta-chlorinated biphenyls with an average chlorine content of 42%. Once released into the environment, commercial mixtures of PCBs undergo slow changes (predominately volatilization and biotransformation), so that patterns of PCBs in samples of food, human milk, or other environmental biota do not resemble any one particular commercial mixture (ATSDR 2000; Brouwer et al. 1998).

PCB congeners that have chlorines at the meta positions (3, 3', 5, or 5' carbons in the phenyl rings) or the para positions (4 or 4' carbons) can assume a co-planar geometry (i.e., the 2 rings can exist in the same plane), which is important in determining binding to the Ah receptor, a mediator of some of the toxic effects of PCBs. Increasing degrees of chlorination at the ortho positions (2, 2', 6, and 6' carbons) leads to increasing steric hinderance that prevents a co-planar geometry. In general, PCBs with no or only a single chlorine at an ortho position are co-planar, whereas congeners with two or more ortho chlorines are non-co-planar. PCBs without ortho chlorines generally account for only minor percentages of total PCBs in commercial PCB mixtures or samples of environmental biota (ATSDR 2000).

## E.1 Toxicokinetics

PCBs can be absorbed via the inhalation, oral, and dermal routes of exposure, and are expected to be absorbed by passive diffusion across cell membranes (ATSDR 2000). Data on absorption of inhaled PCBs are insufficient to estimate rates of absorption, but studies of humans and animals exposed to airborne PCBs provide qualitative information that inhaled PCBs can be absorbed (ATSDR 2000). Ingested PCBs appear to be efficiently absorbed based on studies of infants consuming PCBs in their mothers’ breast milk and studies of animals indicating retention percentages ranging from 60 to 100% of ingested doses. Studies of animals dermally exposed to doses of radiolabeled PCBs for 24 hours reported absorption efficiencies ranging from about 15 to 60% of administered doses based on monitoring of urine for several weeks post-dosing.

Once absorbed, PCBs tend to accumulate in lipid-rich tissues, but PCBs have been detected in other tissues as well (ATSDR 2000). For example, in rats given gavage doses of Aroclors 1254 or 1260, the highest concentrations of PCBs were found in fat tissue, followed by concentrations in kidney, liver, and brain; plasma and muscle tissue showed the lowest concentrations. PCB concentrations in human milk can be high relative to other tissue due to high fat content in breast milk, and PCBs are efficiently transferred to children through breast-feeding. Results from animal studies support the importance of breast-feeding transfer to infants, and further indicate that PCBs can cross the placental barrier and enter the fetus. The amount of PCBs transferred to offspring is expected to be higher during lactation than during gestation. For example, in female rats administered PCBs before gestation, an average of 0.003% of the administered dose was transferred to the fetus, whereas 5% was transferred to sucklings (ATSDR 2000).

Rat studies indicate that different PCB congeners can accumulate to different degrees in different tissues. In rats given gavage doses of Aroclor 1254 (comprised of 2.1% mono-, di-, and tri-chlorinated PCB congeners, 19.1% tetra-, 49.6% penta-, 25.9% hexa-, 2.9% hepta-, and 0.5% octa- and nona-chlorinated PCB congeners), heavily chlorinated congeners (with 6–9 chlorines) accounted for greater percentages of total PCBs in analyzed tissues than in Aroclor 1254 itself (Kodavanti et al. 1998). Most PCBs in Aroclor 1254 have at least one ortho chlorine; PCBs without ortho chlorines account for <3% of PCBs in Aroclor 1254. Hexa- through nona-chlorinated congeners accounted for 29.3% of PCBs in Aroclor 1254, and, in contrast, 70, 66, and 49% of total PCBs in frontal cortical brain, liver, and fat tissues, respectively. Observations that lower chlorinated congeners or congeners with two adjacent unsubstituted carbons (i.e., at the meta and para positions; 3,4 or 3',4' positions) are metabolized more quickly than higher chlorinated congeners or congeners without adjacent unsubstituted carbons (ATSDR 2000; Parham and Portier 1998; Safe 1994) may provide at least a partial explanation of this differential tissue accumulation among PCB congeners.

Hydroxylated PCBs (i.e., phenolic PCBs) are the major metabolites of PCBs in humans and animals, and are formed either by direct catalysis or via arene oxide intermediates by several CYP oxygenase isozymes (ATSDR 2000; Expert Panel 1994; Safe 1994). Phenolic PCBs can be further hydroxylated to form dihydrodiols and catechols, or conjugated with glucuronides or sulfates, which facilitates excretion in bile or urine. Glutathione conjugates are formed from arene oxide intermediates by glutathione S-transferase catalysis and transported to the intestine in the bile (Safe 1994). In the intestine, cleavage of the carbon-sulfur bond by microbes leads to the formation of thiol intermediates, which can be methylated and reabsorbed. Following reabsorption, the methylated thiols can be further oxidized to form methylsulfonyl-PCBs, which have been proposed to be involved in respiratory toxic effects from PCB exposure (Bergman et al. 1992; Brandt and Bergman 1987). Non-ortho-substituted PCBs appear to be preferentially metabolized initially by CYP isozymes that are induced by 3-methylcholanthrene (e.g., CYP1A1 and 1A2), whereas PCBs with multiple ortho substitutions appear to be preferentially metabolized by phenobarbital-inducible isozymes (e.g., CYP2B2, 2B1, and 3A) (ATSDR 2000; Expert Panel 1994). Congeners with mono-ortho substitution appear to be metabolized by both types of CYP isozymes.

Comparison of congener concentrations in commercial PCB mixtures with concentrations in adipose tissue from exposed workers indicates that some PCB congeners are more readily transformed by metabolism than others (ATSDR 2000). For example, both 2,2',4,4',5,5'-hexachlorobiphenyl and 2,2',4,4',6,6'-hexachlorobiphenyl are found in commercial PCB mixtures and in environmental samples, but 2,2',4,4',5,5'-hexachlorobiphenyl was detected in the workers’ adipose tissue and 2,2',4,4',6,6'-hexachlorobiphenyl was not (ATSDR 2000). Results from rat studies indicate that the rate of metabolism decreases as the degree of chlorination on both phenyl rings increase and is dependent on the position of chlorine atoms on the phenyl ring (ATSDR 2000; Parham and Portier 1998; Safe 1984). Higher rates of hydroxylation are expected with PCBs that have two adjacent unsubstituted carbons in a phenyl ring at the 3,4 or 3',4' positions (i.e., meta-para unsubstituted carbons). For example, in humans exposed to PCBs, hexa- and hepta-chlorinated congeners were more slowly cleared from the blood than tetra- and penta-chlorinated congeners, and, among tetra- and penta-chlorinated congeners, those without adjacent unsubstituted carbons were more slowly cleared than those with adjacent unsubstituted carbons. In mice administered one of five tetrachlorobiphenyls, elimination half-lives for the congeners increased in the following order: 2,6,2',6' = 2,3,2',3' < 2,3,5,6 << 3,4,3',4' = 3,5,3',5, consistent with decreasing rate of metabolism in this sequence.

Different PCBs induce different spectrums of CYP isozymes (Connor et al. 1995; Hansen 1998). Commercial mixtures such as Aroclor 1254 and 1242 induce both types of CYP isozymes. Co-planar PCBs without ortho substitution (e.g., the 3,3',4,4'-, 3,3',4,4',5-, and 3,3',4,4',5,5'-congeners) are among the most potent PCB inducers of CYP1A1/1A2 and have the greatest affinity for the Ah receptor. Mono-ortho PCBs with lateral substitutions (e.g., the 2,3,3',4,4'-, 2,3,4,4',5-, 2',3',4,4',5-, 2',3,4,4',5-, 2,3,3',4,4',5-, 2,3,3',4,4',5'-, 2,3',4,4',5,5'-, and 2,3,3',4,4',5,5'-congeners) induce both CYP1A1/1A2 and CYP2B1/2B2 isozymes and have less affinity for the Ah receptor than the non-ortho PCBs. Some di-ortho PCBs induce both types of CYP isozymes and have less affinity for the Ah receptor than the mono-ortho congeners (e.g., the 2,2',3,3',4,4'-, 2,2',3,4,4',5'-, and 2,2',3,3',4,4',5-congeners). In contrast, most congeners with multiple ortho chlorines and one or two para chlorines (e.g., 2,2',4,4'-, 2,2',4,4',5-, 2,2',4,5,5'-, 2,3,3',4',6-, 2,2',4,4',5,5'-, 2,3,3', 4',5,6-, 2,2',3,4,4',5',6-, 2,2',3,4',5,5',6-, 2,2',3,3',4,4',5,5'-, and 2,2',3,3',4,5,5',6'-congeners) induce only the CYP2B1/2B2 and 3A isozymes and essentially do not bind to the Ah receptor.

In general, PCB congeners display a wide range of elimination rates that have been demonstrated in several cases to be associated with the rates at which they are metabolized (i.e., more rapidly metabolized PCBs are more rapidly excreted) (ATSDR 2000). Studies with animals given parenteral or oral doses of PCB mixtures or individual PCBs indicate that excretion of PCBs and their metabolites occurs via feces and urine with much greater amounts excreted in the feces (ATSDR 2000). For example, within 42 days of administration of an intravenous dose of radiolabeled 3,3',5,5'-tetrachlorobiphenyl (a PCB that is more rapidly metabolized than other more highly chlorinated PCBs) to rats, 80% of the dose was excreted in the feces and 6.1% was excreted in the urine. Less than 10% of radioactivity in bile, feces, and urine was parent compound. Within 40 weeks of administration of an intravenous dose of a poorly metabolized PCB (2,2',4,4',5,5'-hexachlorobiphenyl), rats excreted 16% of the dose in feces and 0.8% in the urine. Another significant route of elimination is breast milk; it has been estimated that an infant in an industrialized country may accumulate about 7% of its lifetime PCB body burden during 6 months of breast feeding (ATSDR 2000).

## E.2 Health Effects

Associations have been noted between occupational exposure to commercial mixtures of PCBs and several health effects, including chloracne and other skin changes; various hepatic effects including increased serum levels of liver enzymes and lipids, induction of drug-metabolizing enzymes, and hepatomegaly; decreased birth weight in offspring (of occupationally exposed mothers); and eye irritation (Safe 1994; Swanson et al. 1995).

Studies of cancer mortality in occupationally-exposed workers have not found consistent or strong evidence of carcinogenicity, but findings of increased incidence of liver tumors in studies of rats exposed to commercial PCB mixtures suggest that PCBs are probable human carcinogens (ATSDR 2000; Safe 1994). IARC (1987) classified the human evidence as limited, whereas EPA (2000f) classified the human evidence as inadequate, but suggestive. Some cohort mortality studies of workers exposed during capacitor manufacturing and repair found increased risk for liver, biliary tract, gall bladder, and/or intestinal cancers, but statistically significant increases were not observed in all studies, and clear demonstrations of increasing risk with increasing exposure indices were not found (ATSDR 2000). Most case-control studies examining possible associations between breast cancer in women and concentrations of PCBs in breast tissue or blood found no statistically significant association (ATSDR 2000; Swanson et al. 1995).

Two incidences of consumption of PCB-contaminated cooking oil, one in Japan (the “Yusho” incident) and the other in Taiwan (the “Yucheng” incident), were associated with acne and skin pigmentation in adults and abnormalities in offspring including dark pigmentation of the skin, lower birth weight, and slower development (ATSDR 2000; Safe 1994; Swanson et al. 1995). These incidents are usually cited in discussion of the health effects of PCBs, but it is generally thought that the health effects were due primarily to PCDFs rather than PCBs (ATSDR 2000; Expert Panel 1994; Safe 1994; Swanson et al. 1995).

Studies of people and animals with diets containing Great Lakes fish (contaminated with PCBs and other biopersistent chemicals) provide suggestive evidence that frequent dietary consumption of contaminated fish by child-bearing-aged women may be associated with subtle neurobehavioral effects in their children, but no consistent evidence for associations with impaired reproduction, immune capabilities, or physical birth defects (Buck et al. 1997; Courval et al. 1999; Daly 1991; Dar et al. 1992; Feeley and Jordan 1998; Feeley et al. 1998; Fein et al. 1984; Hertzler 1990; Jacobson and Jacobson 1996; Jacobson et al. 1984, 1985, 1990a, 1990b; Kostyniak et al. 1999; Lonky et al. 1996; Mendola et al. 1995, 1997; Mergler et al. 1998; Restum et al. 1998; Schantz et al. 1999; Stewart et al. 1999, 2000b; Vena et al. 1996). In one prospective study, limited evidence was presented relating maternal PCB exposure levels and deficits in neonatal behavioral development, short-term memory during infancy, and general intellectual ability in early school years (Jacobson and Jacobson 1996; Jacobson et al. 1984, 1985, 1990a). Statistically significant relationships between maternal PCB exposure levels (cord blood concentrations of PCBs with 7–9 chlorines) and deficits in neonatal behavioral development also were found in another more recent prospective study (Lonky et al. 1996; Stewart et al. 1999, 2000b). Studies of people and animals with diets containing contaminated Baltic Sea fish provide suggestive evidence that contaminated fish consumption may be associated with impaired immunological competence or low birth weight, but do not clearly demonstrate dose-response relationships for the potential health hazards (Ross et al. 1995; Rylander and Hagmar 1999; Rylander et al. 1995, 1996, 1998a, 1998b; Svensson et al. 1994). Results from a North Carolina study (Gladen and Rogan 1991; Gladen et al. 1988; Rogan et al. 1986a, 1986b, 1987) and a Dutch study (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994, 1996; Patandin et al. 1998, 1998b, 1999) of breast-fed children provide some evidence that exposure to PCBs in human breast milk at exposure levels in the upper range of background levels or exposure to PCBs in utero may result in mild neurodevelopmental delays in some children. It is plausible that exposure to PCBs may have contributed to these associations, but these studies of possible health effects from environmental exposure to PCB-containing complex mixtures cannot determine with certainty which chemicals may cause the effects or determine possible interactions that may occur among the components.

Oral exposure to commercial mixtures of PCBs has been demonstrated to produce a wide array of toxic effects in animals including:

1. inhibition of body weight gain or body weight loss in rats, rabbits, monkeys, or minks after acute, intermediate, or chronic exposure (ATSDR 2000; Safe 1994);
2. increased porphyrin levels in liver, urine, or kidneys in rats after intermediate exposure (ATSDR 2000; Safe 1994);
3. dermal effects including acne, alopecia, or finger- and toenail loss in monkeys or rats exposed for intermediate or chronic exposure (ATSDR 2000);
4. induction of hepatic levels of Phase I (CYP oxygenases) and Phase II (e.g., UDP-glucuronyltransferases) enzymes (ATSDR 2000; Safe 1994);
5. increased liver weight, increased serum cholesterol, or degenerative liver changes (e.g., fatty changes, necrosis) in rats after acute exposure, in monkeys, rats, or mice after intermediate exposure, and in monkeys or rats after chronic exposure (ATSDR 2000);
6. altered thyroid hormone levels (e.g., T_4_), histology, or weight in adult rats after acute exposure, in rats or mice after acute in utero exposure, and in adult rats after intermediate exposure (ATSDR 2000; Safe 1994);
7. fetal toxicity and decreased fetal survival in rats and hydronephrosis in mice exposed for acute durations in utero, and fetal toxicity and decreased survival in monkeys, rats, mice, rabbits, guinea pigs, or minks exposed for intermediate durations, or in monkeys exposed for chronic durations (ATSDR 2000);
8. altered neurobehavior and/or brain chemistry in adult rats after acute exposure or adult monkeys or rats after intermediate exposure (ATSDR 2000);
9. altered neurobehavior in rats or mice after acute in utero exposure, in offspring of rats or mice exposed for intermediate durations, or in offspring of monkeys exposed for chronic durations (ATSDR 2000);
10. impaired reproductive function or altered reproductive organ weight or structure in adult monkeys, rats, mice, or mink after intermediate exposure, or in adult monkeys after chronic exposure (ATSDR 2000);
11. altered reproductive function or reproductive organ weight or structure in rats after acute in utero exposure (ATSDR 2000);
12. decreased immunological responsiveness (e.g., increased mortality from microbial infection or decreased antibody production in response to foreign blood cells) and/or altered organ weights or histopathology of thymus or spleen in monkeys, rats, mice, rabbits, or guinea pigs exposed for intermediate durations and in monkeys exposed for chronic durations (ATSDR 2000);
13. increased incidence of liver tumors in rats exposed for chronic durations, and promotion (but not initiation) of preneoplastic lesions and tumors in the liver and lung of rats and mice following initiation by other carcinogens such as N-nitrosodiethylamine (ATSDR 2000).

## E.3 Mechanisms of Action

Mechanisms by which the broad array of toxic effects observed in animals orally exposed to PCB mixtures develop are incompletely understood, but there is evidence to suggest that PCB congeners differ qualitatively and quantitatively in biological activities and that multiple and diverse mechanisms are involved in responses to PCB mixtures. Research in the 1970s and 1980s focused on mechanistic similarities between PCBs and CDDs involving initial mediation of effects by the Ah receptor (Poland and Knutson 1982; Safe 1990, 1994), but research through the 1990s has found increasing evidence for the involvement of alternative mechanisms for several PCB-induced effects (Chauhan et al. 2000; Cheek et al. 1999; Fischer et al. 1998; Hansen et al. 1998; Harper et al. 1993a, 1993b; Safe 1994; Tilson and Kodavanti 1998). An in-depth and all-inclusive review of the many recent and ongoing research efforts regarding PCB mechanisms of action is outside of the scope of this profile; rather, an overview of this large body of research is presented with the intent of providing information relevant to public health issues.

### PCB Effects Involving Ah-receptor Dependent Mechanisms

#### INDUCTION OF HEPATIC CYP1A OXYGENASES AND PHASE II ENZYMES

PCBs induce hepatic Phase I enzymes (CYP oxygenases) and Phase II enzymes (e.g., UDP glucuronyltransferases, epoxide hydrolase, or glutathione transferase) to varying degrees and specificities (Connor et al. 1995; Hansen et al. 1998; Safe 1994). Demonstration of relationships between PCB molecular structure and induction of CYP isozymes has provided a framework within which much mechanistic research has been conducted. In general, commercial mixtures of PCBs induce both 3-methylcholanthrene-type (CYP1A1 and 1A2) and phenobarbital-type (CYP2B1, 2B2, and 3A) CYPs. Strong structure-activity relationships have been demonstrated between CYP1A1/1A2 induction in rodents and non-ortho and mono-ortho PCBs, which can assume a coplanar molecular configuration and bind to the Ah receptor (Connor et al. 1995; Hansen et al. 1998; Safe 1994). In structure-activity studies of CYP1A induction in hepatocytes from cynomolgus monkeys by 20 PCBs varying in degree and pattern of chlorine substitution (4–7 chlorines), the most potent inducers were without ortho chlorines (van der Burght et al. 1999). Many PCBs with ortho chlorines (mono-, di-, tri-, and tetra-ortho congeners) displayed no CYP1A induction activity, but a few mono-ortho and multiple-ortho congeners displayed activities that were about 1,000- and 10,000-fold less than the most potent non-ortho congeners, respectively (van der Burght et al. 1999). A working mechanistic hypothesis involves initial binding of coplanar PCBs to the Ah receptor in the cytosol of target cells, transport of the ligand-receptor complex to the nucleus, and subsequent changes in gene expression (e.g., induction of CYP1A1/1A2) leading to toxic responses via subsequent molecular mechanisms that are largely unexplored. Support for this hypothesis comes from the similarity in the array of PCB effects compared with the array produced by 2,3,7,8-TCDD and related halogenated aromatic hydrocarbons via initial Ah-receptor mediation, results from in vitro binding studies, and results from congener-specific in vivo studies of specific endpoints (e.g., enzyme induction and down regulation, body weight, and immunological responses to sheep red blood cells) in mouse strains and rat genders differing in responsiveness to Ah-receptor mediation (Hori et al. 1997; Safe 1990, 1994).

The complexity of Ah-receptor mediated effects on hepatic enzyme levels is illustrated by results from a study with mouse strains differing in Ah-receptor responsiveness and three PCB congeners (Hori et al. 1997). Ah responsive (C57BL/6) and Ah non-responsive (DBA/2 mice) were given single intraperitoneal doses of 3,3',4,4',5-pentachlorobiphenyl, a congener with high Ah receptor affinity, 3,3',4,4'-tetrachlorobiphenyl, a congener with lesser affinity, and 2,2',5,5'-tetrachlorobiphenyl, a low-affinity ligand.

Only the high-affinity 3,3',4,4',5-congener produced body weight wasting in the dose range tested (up to 50 mg/kg) in Ah-responsive C57BL/6 mice, and this effect was accompanied by a decrease in selenium-dependent glutathione peroxidase and an increase in 2 glutathione S-transferase. The effect on levels of these Phase II enzymes was not produced by the other congeners in C57BL/6 mice, and did not occur in DBA/2 mice exposed to any of the congeners, indicating the involvement of Ah-receptor mediation. These Phase II enzymes both play protective roles in scavenging intracellularly generated peroxides and the balance of their activities is likely to influence a cell’s ability to withstand damage from peroxides.

#### BODY WEIGHT WASTING, THYMIC ATROPHY, AND PORPHYRIA

In addition to induction of hepatic levels of CYP1A1/1A2/1B1 and induction or repression of some Phase II enzymes, PCB-induced effects that appear to predominately involve Ah-receptor initiated mechanisms include body weight wasting and thymic atrophy from acute exposure (Hori et al. 1997; Safe 1994) and porphyria and porphyria cutanea tardea (Franklin et al. 1997; Smith et al. 1990a, 1990b). For example, single intraperitioneal doses of 5 mg/kg 3,3',4,4',5-pentachlorobiphenyl, a potent inducer of CYP1A1 and a high-affinity Ah-receptor agonist (relative to other PCBs), produced marked body weight wasting in Ah-responsive C57BL/6 mice, but not in DBA/2 mice, which have a low-affinity Ah-receptor (Hori et al. 1997). Showing a link between Ah-receptor responsiveness and development of uroporphyria, female F344 rats had significantly higher hepatic levels of porphyrins and ethoxyresorufin deethylase activity (an indicator of CYP1A1) in response to exposure to 0.005% Aroclor 1254 in the diet for 15 weeks than did male rats (Smith et al. 1990b). A similar gender-specific correlation between porphyrinogenic response and CYP1A induction was observed in iron-loaded F344 rats exposed to single intraperitoneal doses of 63 mg Aroclor 1254/kg (Franklin et al. 1997). In mice of the Ah-responsive C57BL/6 strain, a single dose of iron-dextran (600 mg Fe/kg), followed by feeding of a diet containing 0.01% Aroclor 1254 for up to 12 months, produced markedly increased hepatic levels of porphyrins and liver enlargement, but this response to iron and Aroclor 1254 was not observed in similarly treated DBA/2 mice (Smith et al. 1990a). Exposure to iron-dextran alone caused a moderate porphyria in C57BL/6 mice, but not in DBA/2 mice, lending support to a postulate that there are constitutive genetic differences between these strains that influence porphyria development and do not involve Ah-receptor mediation (Smith et al. 1990a). One mechanistic hypothesis proposes that induction of CYP1A2 by the Ah-receptor-PCB complex leads to generation of a competitive inhibitor of uroporphyrinogen decarboxylase in the liver and subsequent accumulation of porphyrins (see Franklin et al. 1997).

#### Ah RECEPTOR TEF APPROACH TO HEALTH HAZARD ASSESSMENT

A TEF approach to evaluating health hazards from exposure to complex environmental mixtures containing PCBs, CDDs, and CDFs has been developed and is used to some extent to guide public health decisions because humans are exposed to complex and varying mixtures of these halogenated aromatic hydrocarbons and there are limited toxicological data for these complex mixtures and many of their components (ATSDR 1998; Safe 1990, 1994; van den Berg et al. 1998). PCBs were included in this component-based approach because (1) the spectrum of effects in animals exposed to some PCB mixtures and congeners is similar to the spectrum produced by 2,3,7,8-TCDD (via Ah receptor initial mediation) and (2) coplanar PCBs display Ah receptor binding affinities that were related to their potency in producing health effects in rodents such as body weight wasting and inhibition of immunological responses to sheep red blood cells (Safe 1990, 1994). The TEF approach compares the relative potency of individual congeners, based on in vitro or acute in vivo data, with that of 2,3,7,8-TCDD, the best-studied member of this chemical class, so that the TEF for 2,3,7,8-TCDD is 1. The concentration or dose of each active component in a mixture of concern is multiplied by its TEF to arrive at a TEQ, and the TEQs are added to give the total toxic equivalency of the mixture, which are compared with reference exposure levels for 2,3,7,8-TCDD expected to be without significant risk for producing health hazards. TEFs have recently been recommended by the World Health Organization for 7 CDD, 10 CDF, and 12 PCB congeners (Van den Berg et al. 1998).

Limitations in using the TEF approach for assessing health hazards from PCB-containing environmental media revolve around the inherent assumptions that the components jointly act in an additive manner through a common Ah-receptor initial mechanism and the evidence that Ah-receptor-binding congeners in PCB-containing environmental mixtures are minor components (Hansen 1998; Safe 1998a, 1998b). Several studies have provided evidence of non-additive interactions between specific PCB congeners and between some PCB congeners and 2,3,7,8-TCDD (Safe 1998a, 1998b), and there is evidence, discussed below, that several Ah-receptor-independent mechanisms may make contributions to toxic effects from PCB mixtures.

### PCB Effects Involving Ah-receptor Independent Mechanisms

#### INDUCTION OF HEPATIC CYP2B OXYGENASES

In contrast to the distinct relationships between CYP1A1/1A2 induction, PCB molecular structures, and Ah-receptor initiation of toxic effects, relationships between potency in inducing CYPs 2B1/2B2/3A, PCB structural properties, and toxic effects are less clear (Connor et al. 1995). For example, some PCBs with two ortho chlorines and lateral chlorines induce both types of CYPs and display a very small affinity for the Ah receptor, whereas other di-ortho PCBs with one or two para chlorines predominately induce CYP2B1/2B2/3A and have no measurable affinity for the Ah receptor (Connor et al. 1995; Hansen 1998). Nevertheless, it is clear that PCB induction of phenobarbital-type CYPs is independent of the Ah receptor and that the most potent inducers of CYP have at least two ortho chlorines and one or two para chlorines.

Other PCB-induced effects involving Ah-receptor independent mechanisms include: neurological and neurodevelopmental effects involving changes in brain dopamine levels (Seegal 1996b, 1998; Seegal et al. 1989, 1990; Shain et al. 1991), inhibition of dopamine vesicular uptake (Mariussen et al. 1999), and/or changes in brain cell intracellular calcium homeostasis and related signal transduction processes (Kodavanti and Tilson 1997; Tilson and Kodavanti 1997, 1998; Tilson et al. 1998; Wong and Pessah 1996, 1997; Wong et al. 1997); and tissue injury related to activation of neutrophils (Brown and Gamey 1995; Gamey et al. 1993; Tithof et al. 1995).

#### BRAIN DOPAMINE LEVELS AND NEUROLOGICAL EFFECTS

Aroclor 1254 decreased cellular levels of dopamine in cultured pheochromocytoma cells, which synthesize, store, release, and metabolize dopamine in a manner similar to the intact mammalian central nervous system (Seegal et al. 1989). Daily oral exposure of adult nonhuman primates (Macaca nemestrina) to Aroclor 1016, a commercial mixture of lightly chlorinated PCB congeners, for 20 weeks, likewise, produced decreased dopamine concentrations in brain regions including the caudate, putamen, substantia nigra, and hypothalamus (Seegal et al. 1990). In these brain regions, only three PCB congeners were detected (2,4,4'-trichlorobiphenyl and 2,2',4,4'- and 2,2',5,5'-tetrachlorobiphenyl), suggesting that nonplanar PCBs, which are poor Ah receptor agonists, may have been responsible for the effect. Structure-activity studies of 50 PCB congeners in the pheochromocytoma in vitro system found that the most active congeners had two ortho chlorines (e.g., 2,2',4,6-, 2,2',5,5'-, and 2,2',4,5-tetrachlorobiphenyl) and that congeners that were relatively strong Ah receptor agonists (e.g., 3,3',4,4'-tetrachlorobiphenyl, 3,3',4,4',5-pentachlorobiphenyl) were inactive or had minimal effects on dopamine levels (Shain et al. 1991). However, ortho substitution was not the sole determinant of activity in this system; for example, a congener with four ortho chlorines (2,2',6,6'-tetrachlorobiphenyl) had no effect on dopamine levels in pheochromocytoma cells (Shain et al. 1991). The effect on dopamine levels has been postulated to involve decreased dopamine synthesis via direct or indirect PCB inhibition of tyrosine hydroxylase (Choksi et al. 1997; Seegal 1996b) or L-aromatic amino acid decarboxylase (Angus et al. 1997) and/or decreased uptake of dopamine into vesicles (Mariussen et al. 1999). For example, several congeners that were inactive in causing dopamine level changes in pheochromocytoma cells (e.g., 2,2',6,6'- and 3,3',4,4'-tetrachlorobiphenyl) were much less active in inhibiting vesicular uptake of dopamine than other more active congeners (e.g., 2,2',4,6- and 2,2',4,5'-tetrachlorobiphenyl) (Mariussen et al. 1999).

#### DISRUPTION OF CA^+2^ HOMEOSTASIS AND NEUROLOGICAL EFFECTS

Neurological and/or neurodevelopmental effects from exposure to PCBs also have been hypothesized to involve interference with calcium homeostatic mechanisms and intracellular second messenger systems by PCB congeners that are not effective Ah receptor agonists (see reviews by Kodavanti and Tilson 1997; Tilson and Kodavanti 1998; Tilson et al. 1998). In agreement with structure-activity relationships observed for PCB effects on dopamine levels in pheochromocytoma cells (Shain et al. 1991), 2,2'-dichlorobiphenyl altered intracellular calcium homeostasis in cultured rat cerebellar granule cells (increased free calcium levels and inhibited calcium buffering systems) at non-cytotoxic exposure concentrations (higher concentrations were cytotoxic) (Kodavanti et al. 1993). In contrast, 3,3',4,4',5'-pentachlorobiphenyl, one of the most effective Ah receptor agonists among tested PCBs (Safe 1994), was not cytotoxic in the tested concentration range and did not alter calcium homeostasis to as great an extent as 2,2'-dichlorobiphenyl (Kodavanti et al. 1993). Using phorbol ester binding in rat cerebellar granule cells as a measure of protein kinase C translocation (which is thought to play key roles in cellular signal transduction in neurons and be regulated by several intracellular factors including intracellular levels of free calcium), commercial mixtures of PCBs (Aroclors 1016, 1254, and 1260) were shown to increase protein kinase C translocation in a concentration-dependent manner with varying potencies (Kodavanti et al. 1995). Aroclors 1016 and 1254 were more potent than Aroclor 1260. Examination of 24 PCB congeners showed that the most potent congeners (e.g., 2,2'-dichlorobiphenyl, 2,2',5,5'-tetrachlorobiphenyl, and 2,2',4,6,6'-pentachlorobiphenyl) had multiple ortho chlorines, whereas congeners without ortho chlorines tended to have either no or lower activities (Kodavanti et al. 1995). Similar results were found in structure-activity studies of 24 PCB congeners and their effects on in vitro Ca^+2^ sequestration by microsomes and mitochondria from freshly isolated rat cerebellar cells (Kodavanti et al. 1996). Structure activity relationships for PCB congeners and protein kinase C translocation in rat cerebellar granule cells and Ca^+2^ sequestration were similar to relationships for PCB congener-induced changes in dopamine levels in pheochromocytoma cells. For example, 2,2',5,5'- and 2,2',4,6-tetrachlorobiphenyl were among the most potent congeners and 2,2',6,6'- and 3,3',4,4'-tetrachlorobiphenyl were inactive in all three systems (Kodavanti et al. 1995, 1996; Shain et al. 1991).

One proposed molecular target for PCB disruption of calcium homeostasis that may be involved in neurological and neurodevelopmental effects is ryanodine-sensitive Ca^+2^ channels. Commercial PCB mixtures with intermediate to high degrees of chlorination (Aroclors 1248, 1254, 1260) enhanced ryanodine binding to calcium release channels in sarcoplasmic reticulum membranes from skeletal or cardiac rabbit muscles, and mixtures with lower (Aroclors 1221, 1232) or higher chlorination (Aroclor 1268) showed little enhancement (Wong and Pessah 1996). Examination of selected pentachlorobiphenyls indicated that ortho substitution favored activity; 2,2',3,5',6–pentachlorobiphenyl induced the greatest enhancement of ryanodine binding, whereas the 3,3',4,4',5-isomer did not enhance binding (Wong and Pessah 1996). The 2,2',4,6,6'-isomer with full substitution at the ortho positions produced less enhancement than the 2,2',3,5',6-isomer, indicating that some degree of rotation about the biphenyl bond may be important for full activity. Results from studies with hippocampal slices from freshly dissected rat brains indicated that perfusion with a triortho congener (2,2',3,5',6-pentachlorobiphenyl) enhanced ryanodine binding and inhibited electrophysiological responses to electrical pulse stimulations, but a mono-ortho congener (2,3',4,4'-tetrachlorobiphenyl) showed no enhancement of ryanodine binding and no inhibition of electrophysiological responses to stimulation (Wong et al. 1997). Offspring of rats exposed to gavage doses of 8 or 32 mg/kg/day 2,2',3,5',6-pentachlorobiphenyl on gestation days 10–16 displayed neurobehavioral changes as adults (depressed open field locomotor activity, faster acquisition on a working memory task, and no changes in a delayed spatial alternation task), and changes in ryanodine binding to calcium channels in specific regions of the brain (e.g., decreased in hippocampus and increased in cerebral cortex) (Schantz et al. 1997). Although it is not understood how these changes in ryanodine binding are specifically related to the observed neurobehavioral changes, the results from this series of studies emphasize the potential importance of Ah receptor independent mechanisms in PCB-induced neurological and neurodevelopmental effects.

#### NEUTROPHIL FUNCTION AND IMMUNOLOGICAL EFFECTS AND TISSUE DAMAGE

PCB-induced functional changes in neutrophils may be involved in impaired immune defenses against pathogens or enhanced inflammatory responses (e.g., production of reactive oxygen species and cytolytic enzymes) leading to tissue injury. Incubation of quiescent cultured rat peritoneal neutrophils with Aroclor 1242 stimulated neutrophil production of superoxide anion and induced degranulation in a concentration-dependent manner without producing cytotoxicity (Gamey et al. 1993). In neutrophils that were activated for these functions, Aroclor 1242 produced further increases in superoxide anion production, but inhibited the activated degranulation process. Similar effects were observed when neutrophils were incubated with 2,2',4,4'-tetrachlorobiphenyl, a congener that has little affinity for the Ah receptor and induces phenobarbital-type CYPs, but 3,3',4,4'-tetrachlorobiphenyl, an Ah receptor agonist and inducer of 3-methylcholanthrene-type CYPs, did not affect neutrophil function (Gamey et al. 1993). The effects of 2,2',4,4'-tetrachlorbiphenyl on in vitro production of superoxide anion by neutrophils were inhibited when neutrophils were incubated in the absence of extracellular calcium or in the presence of TMB-8, an antagonist of the intracellular mobilization of calcium (Brown and Gamey 1995). In addition, neutrophil degranulation induced by 2,2',4,4'-tetrachlorobiphenyl was enhanced by coexposure with the calcium ionophore A23187 (Brown and Gamey 1995). A mono-ortho congener, 2,3,4,5-tetrachlorobiphenyl, displayed somewhat different effects on neutrophil functions than those from the 2,2',4,4'-congener; it stimulated degranulation in quiescent and activated neutrophils, but only increased superoxide anion production in activated neutrophils, not in quiescent cells. The results from the neutrophil studies suggest the involvement of an Ah-receptor independent mechanism that involves PCB-induced increases in intracellular calcium or PCB effects on a signal transduction pathway that is dependent on calcium availability (Brown and Gamey 1995).

### PCB Effects Involving Ah-receptor Dependent and Independent Mechanisms

PCB-induced effects that may involve both Ah-receptor dependent and independent mechanisms include liver hypertrophy (Hori et al. 1997); neurodevelopmental effects or reproduction effects involving changes in steroid hormone homeostasis (Arcaro et al. 1999; Connor et al. 1997; Gierthy et al. 1997; Fischer et al. 1998; Li and Hansen 1997; Nesaretnam and Darbre 1997; Nesaretnam et al.1996; Seegal et al. 1997) and/or thyroid hormone disruption (Brouwer et al. 1998; Hansen 1998; Li and Hansen 1996a, 1996b, 1997); immunological effects (Harper et al. 1993a, 1993b; Silkworth and Grabstein 1982; Stack et al. 1999); and cancer through non-genotoxic mechanisms involving promotion of oncogenic cells (Cogliano 1998; Safe 1994) and/or genotoxic mechanisms (Robertson and Gupta 2000).

#### LIVER HYPERTROPHY

Liver hypertrophy in animals is produced by oral exposure to commercial PCB mixtures and appears to involve both Ah-receptor dependent and independent mechanisms. An illustration of this phenomenon is the observation that single intraperitoneal doses of any one of three PCB congeners varying in affinity for the Ah receptor produced liver hypertrophy in Ah responsive (C57BL/6) and Ah non-responsive (DBA/2 mice (Hori et al. 1997). The studied congeners were 3,3',4,4',5-pentachlorobiphenyl, a congener with high Ah receptor affinity, 3,3',4,4'-tetrachlorobiphenyl, a congener with lesser affinity, and 2,2',5,5'-tetrachlorobiphenyl, a low-affinity Ah-receptor ligand.

#### REPRODUCTIVE EFFECTS

There are several studies examining female reproductive function variables in rats (Brezner et al. 1984; Hany et al. 1999; Linder et al. 1974; Sager and Girard 1994), mice (Welsch 1985), rabbits (Seiler et al. 1994), minks (Aulerich and Ringer 1977; Backlin and Bergman 1995; Kihlstrom et al. 1992), and monkeys (Arnold et al. 1995, 1996a; Barsotti et al. 1976) repeatedly exposed orally to commercial PCB mixtures, predominately Aroclor 1254. In general, results from these studies identify minks and monkeys as sensitive species.

In minks, repeated exposure to low doses of Aroclor 1254 or Clophen A-50 (0.4–1.8 mg/kg/day) caused reproductive failure that has been associated with fetal death following embryo implantation (Aulerich and Ringer 1977; Backlin and Bergman 1995; Backlin et al. 1997; Kihlstrom et al. 1992). This effect may predominately involve Ah-receptor mediation, as evidenced by observations that only 1/10 mink exposed to 2.5 ppm Aroclor 1254 in the diet from 1 month prior to breeding through parturition produced offspring, whereas exposure by a similar protocol to 2,2',4,4',5,5'-hexachlorobiphenyl or 2,2',3,3',6,6'-hexachlorobiphenyl at concentrations up to 5 ppm did not influence reproductive performance (Aulerich et al. 1985). In contrast, exposure to dietary concentrations as low as 0.1 ppm 3,3',4,4',5,5'-hexachlorobiphenyl in this study (Auerlich et al. 1985) and 0.05 ppm in another study (Aulerich et al., 1987), caused mortality and prevented the minks from reproducing. Dietary exposure of minks to a fraction of Aroclor 1254, containing only congeners with no ortho-chlorines or a single ortho-chlorine and representing <20% of the total weight of Aroclor 1254, reduced litter size and fetal survival and increased incidence of interrupted pregnancies to a similar degree as doses of the complete Aroclor 1254 mixture (1.3 mg/kg/day) containing the same amount of these congeners (Kihlstrom et al. 1992). These results suggest the importance of Ah-receptor mediation of PCB-induced reproductive impairment in minks.

Another mink study comparing reproductive effects from intraperitoneal doses of 2,2',4,4',5,5'- and 3,3',4,4',5,5'-hexachlorobiphenyl not only reinforces the idea that congeners with high Ah-receptor affinity are more potent than congeners with low Ah-receptor affinity, but also provides evidence that Ah-receptor independent mechanisms may be involved (Patnode and Curtis 1994). Administration of single 20-mg/kg doses of the 2,2',4,4',5,5'-isomer (a poor Ah-receptor agonist that has been detected in wild mink tissues at concentrations 50-fold greater than the 3,3',4,4',5,5'-isomer) to pregnant minks on the approximate date of implantation did not affect the number of implantation sites (assayed 14 days after dose administration), but significantly decreased the number of embryos and embryonic weight, crown-to-rump length, and head length. The 3,3',4,4',5,5'-isomer (at lower dose levels of 0.4 or 0.8 mg/kg) also did not affect the number of implantation sites, but produced more severe effects on embryo survival as well as the weight, crown-to-rump length, and head length of surviving embryos (Patnode and Curtis 1994).

The mechanisms involved in PCB-induced reproductive impairment in minks are unknown, but examination of mid- to late-gestation placentae from minks exposed to Clophen A50 by light and electron microscopy revealed degenerative lesions in maternal (endothelial detachment and thrombosis in maternal vessels) and fetal (trophoblastic disintegration and loss of fetal capillary integrity) tissues (Backlin et al. 1998). Jones et al. (1997) postulated that the mechanisms are likely to be multifactorial given the possibility of direct and/or indirect tissue damaging actions of PCBs and the wide range of reported effects of PCBs on steroid hormone synthesis and functions including PCB regulation of CYP oxygenases that activate or deactivate different endogenous steroid hormones, estrogenic and antiestrogenic effects of PCBs, and PCB regulation of estrogen and progesterone receptor levels (see Battershill 1994; Li and Hansen 1997; Patnode and Curtis 1994).

Impaired ability to conceive and decreased fetal survival have been observed following repeated exposure of female Rhesus monkeys to commercial PCB mixtures. Exposure to dietary levels of 2.5 or 5 ppm Aroclor 1248 (approximately 0.1 or 0.2 mg/kg/day) for 16–19 months (including a 7-month period before breeding with non-exposed males) produced resorptions or abortions in 3/8 and 4/6 impregnated female Rhesus monkeys, respectively, compared with 0/12 in a control group (Barsotti et al. 1976). In this study, 12/12, 8/8, and 6/8 females became impregnated in the 0-, 2.5-, and 5-ppm groups, respectively. Another study fed encapsulated Aroclor 1254 at dose levels of 0, 0.005, 0.02, 0.04, or 0.08 mg/kg/day to female rhesus monkeys for 37 months before breeding with non-exposed males and continued dosing through mating and gestation (Arnold et al. 1995). Incidences of abortions, resorptions, or stillbirths were 2/11, 5/10, 3/4, 2/6, and 4/5 in impregnated monkeys in the control through high-dose groups, respectively; respective incidences for impregnation success were 11/16, 10/16, 4/15, 6/14, and 5/15 (Arnold et al. 1995). Mechanisms for these effects in monkeys are unknown, but microscopic examination of tissues from control and exposed monkeys in the second monkey study found no evidence for an association with endometriosis (Arnold et al. 1996a).

The plausibility that PCB effects on reproductive function (and other functions such as neurobehavior and immunological competence) may involve PCB effects on endocrine functions has led to investigations of the estrogenic and anti-estrogenic activities of PCB mixtures and individual congeners, and the effects of PCBs or related halogenated aromatic compounds on steroid hormone metabolism via induction of Phase I or Phase II enzymes. How these PCB effects are specifically related to PCB effects on reproductive function is unknown, but the results of these investigations provide further evidence that reproductive effects from PCB mixtures may not be restricted to Ah-receptor mediation alone and are likely to involve multiple mechanisms that have yet to be elucidated.

The estrogenic and anti-estrogenic activities of some commercial PCB mixtures, PCB congeners, and hydroxylated derivatives of PCB congeners have been assayed by examining uterine variables in immature or ovariectomized female rodents, cell proliferation or gene expression variables in cultured cells including human breast cancer or HeLa cells, and in vitro binding to estrogen receptor preparations (see Andersson et al. 1999; Arcaro et al. 1999; Battershill 1994; Connor et al. 1997; Gierthy et al. 1997; Hansen 1998; Kramer et al. 1997; Krishnan and Safe 1993; Li and Hansen 1997; Moore et al. 1997; Safe 1999; Safe et al. 1998b for reviews). In general, PCB-induced estrogenic activities have been characterized as weak compared to the endogenous hormone, 17β-estradiol, a wide variability of responses has been observed across types of PCBs and assays indicating the involvement of multiple mechanisms (e.g., direct binding to the estrogen receptor is not the only way that estrogenic or anti-estrogenic physiological effects may be mediated), anti-estrogenic activities have been most strongly associated with PCBs that are Ah receptor agonists, and hydroxylated metabolites of PCBs are postulated to be at least partly responsible for physiological responses to PCBs that may involve changes in estrogen receptor-dependent physiological processes.

Early studies showed that subcutaneous administration of 8 mg of Aroclors 1221, 1232, 1242, or 1248 increased uterine weight and glycogen content in rats, but similar exposure to Aroclors 1254, 1260, 1262, or 1268 did not produce this estrogenic effect (Bitman and Cecil 1970). More recent studies have provided further evidence that PCB mixtures can produce estrogenic responses (albeit weak) and that PCB congeners with multiple ortho chlorines (or their hydroxylated metabolites) may be at least partly responsible for these responses. Intraperitoneal doses of Aroclor 1242 (8 mg/rat on day 20 or 0.08 or 0.32 mg/rat on days 20 and 21) significantly increased uterine wet weight in immature female rats to about 40% of the increase produced by 0.001 mg 17β-estradiol (Jansen et al. 1993). Similar increases in uterine wet weight were produced by exposure to di-ortho congeners or hydroxylated derivatives (0.640 mg 2,2',5,5'-tetrachlorobiphenyl or 0.250 mg 2,4,6-trichloro-4'-hydroxy-biphenyl on days 20 and 21), but not by exposure to a coplanar congener without ortho chlorines (0.160 mg 3,3',4,4'-tetrachlorobiphenyl). In another study, the tetra-ortho congener, 2,2',6,6'-tetrachlorobiphenyl, displayed similarly weak estrogenic responses in an in vitro human breast cancer cell assay and an in vivo immature female rat assay (Arcaro et al. 1999). This congener did not competitively bind in vitro to recombinant human estrogen receptors α and β, but a hydroxylated metabolite, 2,2',6,6'-tetrachloro-4'-hydroxy-biphenyl, competitively bound to estrogen receptor α and produced proliferative responses in the breast cancer assay at concentrations about 10-fold lower than effective concentrations of the parent molecule (Arcaro et al. 1999).

Combined exposure of immature rats to 0.32 mg Aroclor 1242 and 0.001 mg 17β-estradiol produced a response similar to estradiol alone, indicating no obvious anti-estrogenic activity, but combined exposure to 0.001 mg estradiol and 0.160 mg 3,3',4,4'-tetrachlorobiphenyl markedly diminished the estradiol-induced increase in uterine wet weight (Jansen et al. 1993). Anti-estrogenic effects similar to those from 3,3',4,4'-tetrachlorobiphenyl were observed in rodent uterine tissue (Astroff and Safe 1990) and human breast cancer cells (Krishnan and Safe 1993) by other congeners with no or single ortho chlorines (e.g., 3,3',4,4',5-pentachlorobiphenyl, 2',3,3',4,4',5-hexachlorobiphenyl), but commercial PCB mixtures were not anti-estrogenic in the breast cancer cell assay. Whereas the data collected by Krishnan and Safe (1993) suggest that anti-estrogenic activities of PCBs may be related to Ah receptor binding affinity, anti-estrogenic activities of hydroxylated PCB congeners with multiple ortho chlorines have been observed in several assay systems (Connor et al. 1997; Moore et al. 1997; Safe et al. 1998b).

Structure-activity relationships for estrogenic activities of PCB congeners or their metabolites are less clear. Some hydroxylated PCBs (2,4,6-trichloro-4'-hydroxy-biphenyl and 2,3,4,5-tetrachloro-4'-hydroxy-biphenyl) have been demonstrated to competitively bind to mouse estrogen receptor preparations and to increase uterine weight and glycogen in immature mice (Korach et al. 1988). In other estrogenic assays, 2,2',4,4',6-tetrachlorobiphenyl, 2,4,4',6-tetrachloro-4-hydroxy-biphenyl, and 2,4,6-trichloro-4'-hydroxy-biphenyl were equally effective in stimulating proliferation of human breast cancer cells, but only 2,4,6-trichloro-4'-hydroxy-biphenyl caused significant induction of vitellogenin in cultured brown trout hepatocytes (Andersson et al. 1999). A structure-activity study of eight hydroxylated PCBs in a series of in vivo and in vitro estrogenic assays found that structure activity relationships were complex and differed from one assay to the next (Connor et al. 1997; Safe et al. 1998b). For example, all but one of the compounds displayed competitive binding to rat and mouse cytosolic estrogen receptors (affinities ranged from about 10^−3^ to 10^−5^ of 17β-estradiol’s affinity), but no estrogenic activities (wet weight, peroxidase activity, progesterone receptor level) were produced in the uteri of immature rats and mice exposed to three consecutive daily doses of the individual hydroxylated PCB congeners at levels of 25, 50, or 100 mg/kg. In contrast, four of the hydroxylated congeners produced estrogenic effects in cultured human breast cells and HeLa cells (Connor et al. 1997; Safe et al. 1998b).

Complex effects on male reproductive organs and functions have been observed in animals exposed to commercial PCB mixtures including reduced testes weight in adult male offspring of guinea pigs exposed during gestation to Clophen A50 (Lundkvist 1990), reduced testes weight in adult male offspring of female rats exposed from 50 days prior to mating through birth of offspring to 4 mg/kg/day Aroclor 1254 or a mixture of PCBs reflective of the composition of human milk samples (Hany et al. 1999), reduced fertility (without changes in reproductive organ weights, sperm production, or sperm morphology) in adult male offspring of female rats exposed to doses of 8 mg/kg Aroclor 1254 and higher on lactation days 1, 3, 5, 7, and 9 (Sager et al. 1987, 1991), and elevated testes weight and increased sperm production in adult rats exposed to subcutaneous doses of Aroclor 1242 or 1254 (0.4–3.2 mg/day) on postnatal days 0–25 (Cooke et al. 1996). Mechanisms involved in these effects on male reproductive organ development are unknown, but have been postulated to involve developmentally specific periods of responsiveness such as long-lasting elevation of testosterone-metabolizing enzymes from in utero exposure leading to reduced testes weight (Hany et al. 1999) and continued depression of thyroid hormone levels during the neonatal period leading to Sertoli cell proliferation and increased testes weight (Cooke et al. 1996). Whether or not PCB estrogenic and anti-estrogenic effects may be involved in any of these effects is unknown, but decreases in adult testis size and sperm production following early developmental exposure to other estrogenic compounds, such as 2,3,7,8-TCDD, is well documented (Gray et al. 1995).

#### DISRUPTION OF THYROID HORMONE HOMEOSTASIS

Concern that the thyroid hormone system may be important in PCB mechanisms of toxicity stems from mainly two important types of observations (Brouwer et al. 1998; Porterfield and Hendry 1998): (1) extensively corroborated findings in experimental animals that exposure to PCBs in utero and/or during early development (e.g., through breast milk) can deplete levels of circulating thyroid hormone in the fetus or neonate, which may give rise to a hyopothyroid state during development (Collins and Capen 1980; Cooke et al. 1996; Corey et al. 1996; Darnerud et al. 1996; Goldey et al. 1995; Juarez de Ku et al. 1994; Li et al. 1998; Morse et al. 1996; Provost et al. 1999; Rice 1999; Schuur et al. 1998a; Seo and Meserve 1995; Zoeller et al. 2000); and (2) the recognition of the importance of thyroid hormones in normal development of the brain, as evident from neurodevelopmental disorders and deficits associated with hypothyroidism (Boyages 2000). The latter are typified by iodine deficiency (e.g., endemic cretinism), which can produce a wide range of neurodevelopmental deficits, including auditory, motor, and intellectual deficits. These outcomes suggest an importance of thyroid hormones in the normal development of the fetal cochlea, basal ganglia, and cerebral cortex, which begin to develop in humans during the second trimester of gestation. This is also the time in which the fetal thyroid gland becomes functional.

Evidence for a potential thyroid hormone involvement in PCB toxicity rests largely on observations made in experimental animals, including rodents and nonhuman primates. Although the studies differ in design, the emerging picture from these studies is that, depending on dose and duration, PCBs can disrupt the production and disposition of thyroid hormones at a variety of levels. The major findings include: (1) histological changes in the thyroid gland indicative of both stimulation of the gland (e.g., similar to that induced by thyroid stimulating hormone (TSH) or a hypothyroid state) and a disruption of the processing of follicular colloid needed for normal production and secretion of thyroid hormone (Chu et al. 1994, 1995, 1996a, 1996b, 1998; Collins and Capen 1980; Collins et al. 1977; Hansen et al. 1995; Tryphonas et al. 1986b); (2) depression of serum T_4_ and T_3_ levels, which may effectively create a hypothyroid state (Byrne et al. 1987; Collins and Capen 1980; Cooke et al. 1996; Corey et al. 1996; Darnerud et al. 1996; Desauliniers et al. 1997; Goldey et al. 1995; Gray et al. 1993; Hansen et al. 1995; Hood et al. 1999; Juarez de Ku et al. 1994; Kasza et al. 1978; Li et al. 1998; Morse et al. 1996; Price et al. 1988; Provost et al. 1999; Rice 1999; Schuur et al. 1998a; Seo and Meserve 1995; Van Birgelen et al. 1995; Zoeller et al. 2000); (3) increased rates of elimination of T_4_ and T_3_ from serum (Goldey and Crofton 1998); (4) increased activities of T_4_-UDP-GT in liver (Chu et al. 1995; Desauliniers et al. 1997; Morse et al. 1996; Schuur et al. 1998a; Van Birgelen et al. 1995), which is an important metabolic elimination pathway for T_4_ and T_3_; (5) decreased activity of iodothyronine sulfotransferases in the liver, which are also important in the metabolic elimination of iodothyronines (Schuur et al. 1998a, 1998b, 1999); (6) decreased activity of iodothyronine deiodinases including brain Type-2 deiodinase, which provide the major pathways for the production of the active thyroid hormone, T_3_ (Morse et al. 1996; Schuur et al. 1998a); and (7) decreased binding of T_4_ to transthyretin an important transport protein for both T_4_ and T_3_ (Cheek et al. 1999; Darnerud et al. 1996).

The above observations suggest that PCBs can disrupt the production of thyroid hormones, both in the thyroid and in peripheral tissues, can interfere with their transport to peripheral tissues, and can accelerate the metabolic clearance of thyroid hormones. The most convincing evidence that PCBs can exert toxicity by disrupting the thyroid hormone system derives from two studies in rats. In one study, neurobehavioral deficits in pups that experienced exposures to Aroclor 1254 in utero and during nursing, were significantly attenuated by subcutaneous injections of T_4_ that increased serum T_4_ and T_3_ concentrations that were otherwise depressed in the PCB-exposed animals (Goldey and Crofton 1998). While this study examined relatively high doses of Aroclor 1254 (≥1 mg/kg/day), it nevertheless demonstrated neurodevelopmental effects that are directly relevant to observations made in epidemiological studies and to neurological sequelae of fetal hypothyroidism, including motor disturbances and hearing.

In the second study, increased testes weight and sperm production in rats that were administered Aroclor 1254 on postnatal days 1–25 were attenuated by injections of T_4_ on postnatal days 1–25, which also prevented the depression in serum T_4_ concentrations (Cooke et al. 1996). Here again, although produced by relatively large doses of Aroclor 1254 (≥40 mg/kg/day, subcutaneous), similar effects can be produced by other hypothyroid-inducing agents, including 6-propyl-2-thiouracil (PTU). Furthermore, the effects observed may reflect a disruption of the normal sexual maturation process, which is known to be associated with neonatal hypothyroidism in humans (Longcope 2000).

The effects PCBs on thyroid hormone status appear to involve Ah-receptor mediated actions as well as actions that appear to be independent of the Ah receptor. Depressed levels of serum T_4_ have been observed in rats given oral doses of coplanar PCB congeners (Desauliniers et al. 1997; Van Birgelen et al. 1994b) or di-ortho-substituted congeners that have relatively low affinity for the Ah receptor (Ness et al. 1993; Van Birgelen et al. 1992). At least one potential Ah-receptor mediated mechanism for this effect is the induction of UDP-GT, which catalyzes the metabolic elimination of T_4_ to the T_4_-glucuronide conjugate (Desauliniers et al. 1997; Van Birgelen et al. 1995). However, the UDP-GT mechanism does not appear to be important in the depression of T_4_ levels produced by non-coplanar PCBs. Li and Hansen (1996b) observed depressed serum T_4_ levels in rats administered a PCB mixture extracted from soil. Treatment of the mixture with activated charcoal greatly reduced the content of co-planar PCBs in the mixture, substantially decreased the potency of the mixture for inducing UDG-GT and EROD, but had little effect on the potency for depressing T_4_ levels. This suggests that an Ah-independent mechanism may exist that is not related to UDP-GT induction.

PCBs, including poly-ortho-substituted PCBs, which have a very low affinity for the Ah receptor, inhibit the binding of T_4_ to transthyretin, an important transport protein for both T_4_ and T_3_ (Chauhan et al. 2000; Cheek et al. 1999; Darnerud et al. 1996). Inhibition of binding of thyroid hormones to transthryetin could alter hormone delivery to target tissues, including the brain, and could also result in depressed levels of serum total TT_4_ or TT_3_ (Brouwer et al. 1998).

#### IMMUNOLOGICAL EFFECTS

Studies with inbred mice strains differing in Ah-receptor responsiveness indicate that immunosuppression from PCB mixtures involves Ah-receptor mediation (e.g., Harper et al. 1993a; Silkworth and Grabstein 1982), but there is evidence that other mechanisms also may contribute to PCB-induced immunological effects (Harper et al. 1993a, 1993b; Stack et al. 1999). Illustrating the importance of Ah-receptor mediation for some PCB congeners, Ah-responsive C57BL/6 mice given single intraperitoneal doses of 100 mg/kg 3,3',4,4'-tetrachlorobiphenyl showed marked decreases in the number of splenic plaque-forming cells (PFCs) formed in response to immunization with sheep red blood cells (sheep red blood cells (SRBC), which are T-cell dependent antigens) compared with similarly treated Ah-non-responsive DBA/2 mice (Silkworth and Grabstein 1982). In addition, ED50 values for 2,3,7,8-TCDD, three CDFs, and two PCBs without ortho substitution (3,3',4,4',5-pentachlorobiphenyl and 3,3',4,4',5,5'-hexachloro-biphenyl) in this immunotoxicity assay were lower in C57BL/6 mice than in DBA/2 mice, and the order of immunotoxic potency of these six compounds was the same as that for potency in inducing CYP1A1 (Harper et al. 1993a). In another study, a series of four hexachlorinated biphenyls with differing chlorine substitution patterns displayed varying ED50 values in the same immunotoxicity assay as follows: 2, >1,000, 120, and >1,000 µmol/kg for a mono-ortho (2,3,3',4,4',5'-), a di-ortho- (2,2',4,4',5,5'-), a tri-ortho-(2,2',4,4',5',6-), and a tetra-ortho-isomer (2,2',4,4',6,6'-), respectively (Harper et al. 1993b). Harper et al. (1993b) concluded that immunotoxic potency decreases (i.e., ED50s increase) with increasing ortho-chlorine substitution of PCBs, but, as shown above, the decrease was not monotonic with increasing degree of chlorination. Furthermore, this relationship did not apply to more highly chlorinated PCBs with three or four ortho chlorines that are inactive as Ah-receptor agonists and only minimally induce CYP1A1 (Harper et al. 1993b). Three nonachlorobiphenyls (2,2,’3,3',4,4',5,5',6-, 2,2,’,3,3',4,4',5,6,6'-, and 2,2',3,3',4,5,5',6,6'-nonachlorobiphenyl) and decachlorobiphenyl displayed ED50s for inhibition of the splenic PFC response to SRBC in C57BL/6 mice that were less than those for hexachlorobiphenyl isomers with multiple ortho chlorines reported above: 15, 7, 17, and 35 µmol/kg, respectively. These results are consistent with the hypothesis that some PCBs induce immunotoxicity via Ah-receptor independent mechanisms. In an in vitro assay of cell proliferation in response to lipopolysaccharide (a T-cell independent antigen), Aroclors 1221, 1242, 1254, or 1260 inhibited the proliferative response similarly in splenocytes from either C57BL/6 or DBA/2 mice (Stack et al. 1999). Two non-ortho and two mono-ortho PCBs that have been demonstrated to be effective Ah-receptor agonists and CYP1A1 inducers did not inhibit the in vitro proliferative response to lipopolysaccharide, but two di-ortho congeners (2,2',3,4,4',5- and 2,2',4,4',5,5'-hexachlorobiphenyl) significantly inhibited the response. These in vitro results provide supporting evidence for the existence of mechanisms of PCB immunotoxic actions that are independent of the Ah receptor.

#### CANCER

Lifetime oral exposure to any one of four commercial PCB mixtures (Aroclors 1016, 1242, 1254, and 1260) has been demonstrated to produce liver tumors in female rats; Aroclor 1260 also induced liver tumors in male rats (Mayes et al. 1998). Mixtures with high chlorination content (e.g., Aroclor 1254) were generally more potent than mixtures with low chlorine content (e.g., Aroclor 1016) (Mayes et al. 1998). Tumor promotion by commercial PCB mixtures following initiation by a variety of chemical agents also has been investigated in a number of animal systems including rat liver, rat kidney, mouse skin, and newborn mouse liver and lung (see Silberhorn et al. 1990 for review). The tumor promoting effect of extended exposure to PCB mixtures was demonstrated principally in the liver of rats; there is some evidence that PCB mixtures also can promote tumors in mouse lung and mouse skin, but not in rat kidneys. The mechanism of PCB-induced cancer is poorly understood, but there is evidence to suggest that both Ah-receptor dependent and independent mechanisms may be involved.

PCB promotion of tumors does not appear to be solely an Ah-receptor mediated process, since individual congeners that are not Ah receptor agonists have tumor promotion capabilities in animal systems. For example, 2,2',5,5'-tetrachlorobiphenyl, 2,2',4,4'-tetrachlorobiphenyl, and 2,2',4,4',5,5'-hexachlorobiphenyl were shown to promote liver tumors in female Sprague-Dawley rats (Hemming et al. 1993; Preston et al. 1985). In addition, 2,2',5,5'-tetrachlorobiphenyl, 2,2',3,3',4,4'-hexachlorobiphenyl, and 2,2',4,4',5,5'-hexachlorobiphenyl were potent inhibitors of in vitro gap junctional cellular communication, an assay that is indicative of tumor promotion capacity (Bager et al. 1997; De Haan et al. 1996). A general working mechanistic hypothesis for PCB promotion of liver tumors involves indirect stimulation of cell proliferation following cell or tissue injury by reactive metabolites of PCBs (Silberhorn et al. 1990). Alternatively, the cell injury could be caused by increased intracellular concentrations of other reactive species (e.g., superoxide anion or other reactive oxygen species) caused by an overall imbalance from PCB-induced perturbations of cellular biochemical processes, including induction of CYP oxygenases and glutathione S-transferases, repression of selenium-dependent glutathione peroxidases, and/or disruption of calcium homeostatic processes and signal transduction pathways (Silberhorn et al. 1990).

PCB mixtures have not shown consistent tumor initiating activity in animal initiation-promotion protocols (Silberhorn et al. 1990), but demonstration that chronic oral exposure to commercial PCB mixtures induced liver tumors in female rats (Mayes et al. 1998) suggests that PCBs may have both tumor initiating and promoting activities. Although PCB mixtures generally have been found to be inactive as mutagens in Salmonella typhimurium strains and in several other tests of genotoxicity that may be predictive of tumor initiation capability (see Silberhorn et al. 1990 for review), in vitro studies with rat microsomes have indicated that metabolism of lower chlorinated PCBs (e.g., 4-chlorobiphenyl, 3,4-dichlorobiphenyl, and 3,4,5-trichlorobiphenyl) can lead to covalently modified macromolecules including proteins and DNA (see Robertson and Gupta 2000 for review). Studies demonstrating the Ah-receptor dependence or independence of this potential genotoxic effect from PCBs were not located. The available data indicate that PCBs are not potent genotoxicants, but the possible involvement of genotoxic mechanisms (involving covalent modification of proteins and/or DNA) in the development of PCB-induced cancer is not without some experimental support.

The relative contribution that Ah-receptor dependent and independent mechanisms may make to carcinogenic responses to PCB mixtures is unknown. Safe (1994) compared carcinogenic responses of female rats to 2,3,7,8-TCDD in the diet with responses of female rats of the same strain to Aroclor 1260 in the diet using the TEF approach. TCDD at a TEQ feed concentration of 2,100 ppt induced hepatic adenocarcinomas in 11/50 (22%) rats, whereas a TEQ of only 1,040 ppt from Aroclor 1260 induced adenocarcinomas in 24/47 (51%) rats. For this situation, the TEF approach markedly underestimated the carcinogenic response to Aroclor 1260. A possible explanation is that PCB congeners that are not Ah receptor agonists and are abundant in Aroclor 1260 make significant contributions to the mixture’s carcinogenicity. Although this comparison suggests that the TEF approach may underestimate cancer responses to complex PCB mixtures, another study of the tumor promotion activity of a simpler mixture of two CDDs, one CDF, and three PCBs in female rats found that the TEF approach overestimated the observed response by a factor of about 2 (van der Plas et al. 1999). The mixture contained 2,3,7,8-TCDD, 1,2,3,7,8-pentachlorodibenzo-p-dioxin, 2,3,4,7,8-pentachlorodibenzofuran, 3,3',4,4',5- and 2,3',4,4',4-pentachlorobiphenyl, and 2,3,3',4,4',5-hexachlorobiphenyl at relative levels found in Baltic Sea herring. The rats were initiated with an injection of diethylnitrosoamine, 24 hours after a partial hepatectomy, and were administered weekly subcutaneous injections of the mixture for 20 weeks starting 6 weeks after initiation. The volume and volume fraction of glutathione S-transferase-positive altered hepatic foci were taken as indicators of tumor promotion activity in this study (van der Plas et al. 1999). Although the composition of this mixture reflected relative concentrations and accounted for >90% of total TEQs in Baltic Sea herring, it did not contain PCBs with multiple ortho chlorines which comprise the predominant bulk of PCB weight in most commercial and environmental mixtures. For example, non-, mono-, and di-ortho congeners accounted for <1, 18, and 82% of PCB weight per gram of fat in human milk samples from Italy (Larsen et al. 1994). Another group of rats was similarly treated with the same synthetic mixture plus a di-ortho PCB congener (2,2',4,4',5,5'-hexachlorobiphenyl), which is one of the predominant PCB congeners in environmental mixtures and has minimal Ah receptor agonist activity (van der Plas et al. 1999). Mean foci volume and foci volume fraction were increased in rats treated with the supplemented mixture compared with the mixture without the di-ortho congener, but the observed responses were still less than that predicted by the TEF approach. Better understanding of the relative contributions of Ah receptor dependent and independent mechanisms to the carcinogenicity of PCB mixtures awaits further research.

## E.4 Health Guidelines

ATSDR (2000) derived an intermediate oral MRL for PCB mixtures of 0.03 µg/kg/day based on a LOAEL of 0.0075 mg/kg/day for neurobehavioral alterations in infant monkeys that were exposed to a PCB congener mixture representing 80% of the congeners typically found in human breast milk (Rice 1997, 1998, 1999; Rice and Hayward 1997, 1999). The infant monkeys were given oral doses of 0 or 0.0075 mg/kg/day from birth to 20 weeks of age. The dose level was selected to be equivalent to an approximate daily intake of a nursing human infant whose mother’s milk contains 50 ppb PCBs. Treated monkeys showed decreases and variable increases in response latencies across three tasks of nonspatial discrimination reversal, retarded acquisition of a delayed alternation task, increased errors at short delay task responses, and alterations in fixed-interval and fixed-ratio performance tasks. The findings were interpreted to suggest that post-natal PCB exposure resulted in impaired learning, impaired perserverative behavior, and/or inability to inhibit inappropriate responding. To derive the MRL, the LOAEL was divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR (2000) derived an chronic oral MRL for PCB mixtures of 0.02 µg/kg/day based on a LOAEL of 0.005 mg/kg/day for decreased antibody response to sheep red blood cells in Rhesus monkeys exposed to self-ingested capsules of Aroclor 1254 in a glycerol/corn oil mixture (Tryphonas et al. 1989, 1991). The LOAEL was divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

Because consensus has emerged on the inappropriateness of assessing environmental PCBs as if they were Aroclors, EPA has developed an approach for assessing cancer risk from environmental PCBs by considering both toxicity and environmental processes (Cogliano 1998; EPA 1996; IRIS 2001). This approach uses animal studies of commercial PCB mixtures to develop a range of human cancer potency estimates and then considers the effect of environmental processes to determine appropriate values for representative classes of environmental mixtures. Guidance is provided for assessing cancer risks from different exposure pathways, less-than-lifetime and early-life exposures, and mixtures containing dioxin-like constituents.

## E.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to PCB mixtures were derived for endpoints affected by PCBs and one or more of the other chemicals in the CDD-hexachlorobenzene-DDE-methylmercury-PCB mixture that is the subject of this Interaction Profile. The relevant endpoints for PCBs in this mixture include hepatic, endocrine, immunological, neurological, reproductive, and developmental effects. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (2000), and in particular, the oral LSE table.

### Hepatic Effects

Several studies of groups of humans exposed to PCBs have reported associations between exposure and changes in indices of hepatic damage (e.g., increased serum levels of aspartate aminotransferase), but limitations in study design, such as lack of appropriate controls or adjustment of potential confounding variables, preclude establishing a causal relationship from the human data (ATSDR 2000). In contrast, studies of orally exposed animals have reported a broad spectrum of PCB-induced hepatic effects including hepatic enzyme induction, liver enlargement, hepatic porphyria, and histopathologic changes in liver tissue ranging from hepatocellular hypertrophy and vacuolization to fatty degeneration, hepatocellular necrosis, bile duct hyperplasia, and liver tumors (ATSDR 2000). The lowest exposure levels associated with liver changes in available animal studies are 0.04 mg/kg/day (no NOAEL was identified) for decreased serum cholesterol in Rhesus monkeys exposed to Aroclor 1254 for 37 months (Arnold et al. 1993a, 1993b), 0.08 mg/kg/day (with a NOAEL of 0.04 mg/kg/day) for increased relative liver weight in Rhesus monkeys exposed to Aroclor 1254 for 72 months (Arnold et al. 1997), 0.2 mg/kg/day (no NOAEL was identified) for hepatocyte necrosis and biliary tract hypertrophy in Rhesus monkeys exposed to Aroclor 1254 for 12 or 28 months (Tryphonas et al. 1986a, 1986b), and 1 mg/kg/day (no NOAEL was identified) for hepatocellular hypertrophy and increased levels of serum enzymes in male rats exposed to Aroclor 1254 or 1260 for 24 months (Mayes et al. 1998). Applying an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from monkeys to humans, and 10 for human variability) to the LOAEL of 0.04 mg/kg/day for decreased serum cholesterol in Rhesus monkeys (Arnold et al. 1993a, 1993b) yields a TTD_HEPATIC_ of 0.1 µg/kg/day for PCB mixtures.

### Endocrine Effects

Studies examining possible associations between PCB exposure and disruption of thyroid hormone status in humans have not found consistent evidence for this type of PCB endocrine effect, but animal studies firmly establish causal relationships between PCB exposures and several types of endocrine effects including disruption of thyroid structural integrity, disruption of thyroid hormone homeostasis, and impaired reproductive function and development that may involve disruption of steroid hormone homeostasis (ATSDR 2000). The lowest oral exposure levels associated with adverse endocrine effects in animals include 0.09 mg/kg/day (no NOAEL was identified) for decreased serum thyroid hormone levels in rats exposed to Aroclor 1254 for 5 months (Byrne et al. 1987); 0.25 mg/kg/day (with a NOAEL of 0.05 mg/kg/day) for decreased serum levels of adrenal hormones in rats exposed to Aroclor 1254 for 5–7 months (Byrne et al. 1988); 0.1 mg/kg/day (no NOAEL was identified) for decreased serum thyroxin levels in rats exposed to Aroclor 1254 for 15 weeks (Gray et al. 1993); 0.1 mg/kg/day (no NOAEL was identified) for decreased serum levels of T3 and T4 in offspring of rats exposed to Aroclor 1254 from gestation day 1 through post-partum day 31 (Provost et al. 1999); and 0.2 mg/kg/day (no NOAEL was identified) for thyroid desquammation in monkeys exposed to Aroclor 1254 for 28 months (Tryphonas et al. 1986b). Dividing the rat LOAEL of 0.09 mg/kg/day for decreased serum thyroid hormone levels produced by intermediate-duration exposure (Byrne et al. 1987) by an uncertainty factor of 1,000 (10 for the use of a LOAEL, 10 for extrapolating from rats to humans, and 10 for human variability) yields a TTD_ENDOCRINE_ of 0.1 µg/kg/day. This value is expected to be protective of chronic-duration exposure because of the large uncertainty factor.

### Immunological Effects

Studies of PCB-exposed groups of humans have reported immune system effects such as increased susceptibility to respiratory tract infections and decreased serum levels of IgA and IgM antibodies, but provide insufficient evidence to conclusively establish a causal relationship between immune system impairment and exposure (ATSDR 2000). In contrast, studies of rats, mice, guinea pigs, and rabbits exposed to commercial mixtures of PCBs have clearly shown PCB-induced immune system effects such as splenic and thymic atrophy, reduced antibody production against foreign antigens, and increased susceptibility to bacterial infection (ATSDR 2000). Monkeys appear to be particularly susceptible to PCB immunotoxicity. The lowest exposure level associated with immune effects in animals orally exposed to PCB mixtures is 0.005 mg/kg/day for decreased IgM and IgG antibody responses to sheep red blood cells in female Rhesus monkeys exposed to Aroclor 1254 for 23 months (Tryphonas et al. 1989). No NOAEL was identified in this study. As described in Section E.4 above, this LOAEL serves as the basis of the chronic oral MRL for PCBs of 0.02 µg/kg/day.

### Neurological Effects

Subtle neurobehavioral changes have been observed in studies of children of mothers consuming large amounts of Great Lakes fish contaminated with PCBs and other biopersistent pollutants (ATSDR 2000). Deficits in measures of neurological development have been associated with increasing indices of PCB exposure, but precise and accurate adjustment for possible confounding variables has not always been possible in these studies. Studies in animals support the human data. Neurobehavioral changes have been observed in rats and monkeys following pre- and/or postnatal exposure to commercial Aroclor mixtures, experimental mixtures of PCBs similar to those found in human breast milk, single PCB congeners, and contaminated fish from the U.S. Great Lakes (ATSDR 2000). As described in Section E.4 above, ATSDR (2000) derived the intermediate oral MRL of 0.03 µg/kg/day for PCB mixtures based on a LOAEL of 0.0075 mg/kg/day (no NOAEL was identified) for neurobehavioral changes in infant monkeys that were orally exposed from birth to 20 weeks of age to a synthetic mixture of PCBs representing 80% of the PCB congeners found in samples of human breast milk and an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolating from monkeys to humans, and 10 for human variability). The intermediate-duration oral MRL is only slightly above the chronic oral MRL of 0.02 µg/kg/day (based on immunological effects in adult monkeys), and is expected to provide protection against possible neurological and neurodevelopmental effects from chronic exposure.

### Reproductive Effects

Some studies examining reproductive endpoints in PCB-exposed humans found suggestive indications that exposure to PCBs may be associated with menstrual disturbances in women and effects on sperm in men, but no consistent or sufficient evidence for obvious reproductive impairment (ATSDR 2000). In contrast, the reproductive toxicity of oral exposure to PCBs is well established in animals. Effects in female animals include: prolonged estrus, decreased sexual receptivity, and reduced implantation rate in adult rats and/or their offspring exposed before sexual maturation; decreased conception rate in mice; partial or total inhibition of reproductive capability in minks; and prolonged menstruation and decreased fertility in monkeys (ATSDR 2000). Effects in male animals include altered reproductive organ morphology, impaired sperm production, and impaired fertility in male rats and mice exposed before sexual maturation (ATSDR 2000). The lowest oral exposure levels associated with adverse reproductive effects include 0.9 mg/kg/day (with a NOAEL of 0.2 mg/kg/day) for decreased reproduction rates and litter size in minks exposed to Aroclor 1254 for 21 weeks (Aulerich and Ringer 1977); 0.1 mg/kg/day (no NOAEL was identified) for increased menstrual length in Rhesus monkeys exposed to Aroclor 1248 for 7 months (Barsotti et al. 1976); 0.1 mg/kg/day (no NOAEL was identified) for decreased spermatogenesis and libido in male Rhesus monkeys exposed to Aroclor 1248 for 17 months (Allen and Norback 1976); and 0.02 mg/kg/day (with a NOAEL of 0.005 mg/kg/day) for reduced conception rate in female Rhesus monkeys exposed to Aroclor 1254 for 37 months (Arnold et al. 1995). Applying an uncertainty factor of 30 (3 for extrapolation from monkeys to humans and 10 for human variability) to the NOAEL of 0.005 mg/kg/day for reduced conception rate in monkeys (Arnold et al. 1995) yields a TTD_REPROD_ of 0.2 µg/kg/day.

### Developmental Effects

The development of the neurological system appears to be a target of critical public health concern associated with pre- and/or post-natal exposure to PCB mixtures (ATSDR 2000). Subtle neurobehavioral effects suggesting impaired learning or perserverative behavior have been observed in monkeys exposed from birth to 20 weeks to oral doses as low as 0.0075 mg/kg/day (Rice 1997, 1998, 1999; Rice and Hayward 1997, 1999). This dose was estimated to correspond to PCB levels in human breast milk of 50 ppb. As discussed in Section E.4 above, these findings serve as the basis of the intermediate oral MRL of 0.03 µg/kg/day. This value is only slightly above the chronic oral MRL of 0.02 µg/kg/day based on impaired immune response in adult monkeys and is expected to be protective of neurodevelopmental effects from chronic oral exposure to PCBs.

### Summary (TTDs for PCBs)

TTD_HEPATIC_ = 0.1 µg/kg/day (1×10^−4^ mg/kg/day)

TTD_ENDOCRINE_ = 0.1 µg/kg/day (1×10^−4^ mg/kg/day)

MRL_(IMMUNO)_ = 0.02 µg/kg/day (2×10^−5^ mg/kg/day; chronic MRL)

MRL_(NEURODEVELOP)_ = 0.03 µg/kg/day (3×10^−5^ mg/kg/day; intermediate MRL)

TTD_REPRO_ = 0.2 µg/kg/day (2×10^−4^ mg/kg/day)