# Appendix C Background Information for p,p’-DDE

The p,p’-isomers are the principal forms of DDT (1,1,1-trichloro-2,2-bis(p-chlorophenyl)ethane) and its derivatives found in the environment because technical grade DDT typically has contained 65–80% p,p’-DDT, 15–21% o,p’-DDT, traces of o,o’-DDT, and up to 4% of p,p’-DDD (ATSDR 1999a). p,p’-DDE (1,1-dichloro-2,2-bis(p-chlorophenyl)ethylene) is the major degradation and metabolic product of p,p’-DDT found in the environment principally because it is metabolized very slowly and accumulates in fatty tissue. In the ensuing discussion, DDT, DDE, or DDD refer to the p,p’-isomers, unless specified otherwise.

## C.1 Toxicokinetics

As reviewed by ATSDR (1999a), results from studies of humans and animals indicate that DDT, DDE, and DDD are absorbed following inhalation, oral, and dermal exposures. Animal studies indicate that gastrointestinal absorption of these compounds is enhanced when they are dissolved in digestible oils and that absorption occurs predominately via the intestinal lymphatic system with only a minor portion of absorption occurring into the portal blood. DDT, DDE, and DDD are lipid soluble compounds that once absorbed are readily distributed via the lymph and blood to all tissues and are stored in proportion to the lipid content of the tissue (ATSDR 1999a). DDT and DDE selectively partition into fatty tissue and human breast milk. Studies of female rats exposed to oral doses of DDE indicate that developing offspring are exposed to DDE via transplacental transfer and through maternal milk and that lactational transfer is the major route of transfer. Studies of metabolism in humans and animals indicate that ingested DDT is reductively dechlorinated to DDD, which is further degraded through several intermediates to DDA (2,2-bis(p-chlorophenyl)acetic acid), the major urinary metabolite. DDT is converted to DDE by dehydrodechlorination at a slower rate, and further metabolism of DDE (eventually to DDA) is slow, leading to accumulation of DDE in fatty tissue. Metabolites are predominately excreted in the urine after conjugation with glycine, serine, aspartic acid, or glucuronic acid. DDT, DDE, and DDD have been shown to be inducers of cytochrome P450 IIB proteins and, to a lesser extent, cytochrome P450 IIIA proteins, but not cytochrome P450 1A proteins. Results from human and animal studies indicate that DDT metabolites are primarily excreted as conjugates in the urine, but some excretion also occurs via the feces (by biliary excretion) and breast milk.

## C.2 Health Effects

Acute, high-dose oral exposure to DDT is well known to primarily affect the nervous system producing symptoms such as paresthesia of the mouth and face, hyperexcitability to stimuli, tremor, headache, nausea, and convulsions (ATSDR 1999a). Studies in animals indicate that repeated oral exposure to p,p’-DDT or its principal accumulating metabolite, p,p’-DDE, can also have adverse effects on the liver, immunological system, nervous system, and male reproductive organs (ATSDR 1999a). Chronic-duration oral exposure to p,p’-DDE produced increased incidence of hepatic fatty metamorphosis in rats exposed to about 31 mg p,p’-DDE/kg/day and hepatic focal necrosis in hamsters exposed to about 48 mg p,p’-DDE/kg/day (ATSDR 1999a). Clinical signs of neurological impairment (hunched appearance) were observed in mice and rats after 8 and 22 weeks exposure to oral doses of 59 and 27 mg p,p’-DDE/kg/day, respectively (ATSDR 1999a). Immunosuppression from repeated exposure to p,p’-DDE or p,p’-DDT is also likely as evidenced by suppressed humoral and cell-mediated immunological responses (to ovalbumin) in rats after dietary exposure to 200 ppm p,p’-DDT or p,p’-DDE (about 20 mg/kg/day) for 6 weeks (Banerjee et al. 1996). Studies in rats show that p,p’-DDE is a competitive inhibitor of androgen binding to the androgen receptor and inhibitor of subsequent expression of genes important in the development of male reproductive organs and in maintenance of their function in adulthood (Kelce et al. 1995; 1997; Loeffler and Peterson 1999). Exposure of rats to several oral doses of 100 mg p,p’-DDE/kg/day during gestation, prepubescence, or adulthood produced anti-androgenic effects including decreased anogenital distance at birth, delayed onset of puberty, and decreased seminal vescicle and ventral prostate weights accompanied by inhibition of androgen-dependent gene expression in the ventral prostate (Kelce et al. 1995). Estrogenic effects from exposure to technical-grade DDT are thought to be due to the o,p’-isomer of DDT which binds the estrogen receptor and induces estrogenic effects such as increased ovarian weight; p,p’-DDT and p,p’-DDE are ineffective at binding to the estrogen receptor (ATSDR 1999a; Kelce et al. 1995). Multigenerational reproductive studies of animals orally exposed to p,p’-DDE have not been conducted, but no significant changes in reproductive endpoints have been observed in several multigenerational studies in mice, rats, or dogs exposed to technical-grade DDT or p,p’-DDT at low doses (generally <10 mg/kg/day) that did not produce overt neurological symptoms such as tremors (ATSDR 1999a). Studies examining the effects of p,p’-DDE on neurological development were not located, but mice given single oral doses of 0.5 mg p,p’-DDT/kg at the peak of neonatal brain development (10 days after birth) showed changes in motor activity in response to being placed in a new environment when they were adults, indicating impaired development of nonassociative learning or control of motor activity capabilities (ATSDR 1999a; Eriksson et al. 1990, 1992).

Studies of agricultural and pest control workers exposed to DDT have not found consistent evidence of DDT carcinogenicity (ATSDR 1999a). A possible association between breast cancer and levels of DDT, DDE, and/or DDD in tissues has been suggested by the results from some case-control studies, but not by results from others (ATSDR 1999a). Chronic dietary exposure to p,p’-DDE produced increased incidence of liver tumors in mice and hamsters and increased incidence of thyroid tumors in female rats (IRIS 2001). Chronic dietary exposure to technical-grade DDT produced increased incidence of liver tumors in mice and rats (IRIS 2001).

## C.3 Mechanisms of Action

There is evidence to indicate that DDT acts on the central nervous system by interfering with sodium ion channels and potassium ion gates in neuronal membranes and by inhibiting a specific neuronal ATPase (ATSDR 1999a). At sufficient doses, these effects can cause repetitive firing of action potentials along the neuron. Studies regarding the mode of action of p,p’-DDE on nervous system function apparently are not available (ATSDR 1999a), but the close structural similarity to p,p’-DDT suggests that similar modes of actions may operate.

Results from in vitro and in vivo studies of rats exposed to p,p’-DDE as adults or in utero and during lactation suggest that the effects of DDT on the male reproductive system may be mediated by p,p’-DDE inhibition of binding of androgens to the androgen receptor (ATSDR 1999a). Results from in vivo and in vitro tests for estrogenic activity indicate that o,p’-DDT and o,p’-DDE are more estrogenically potent (by mimicking natural estrogens) than are p,p’-DDT and p,p’-DDE (ATSDR 1999a), but the o,p’-isomers are present in the environment at much lower concentrations than the p,p’-isomers.

It has been hypothesized that DDT and DDE produce degenerative effects in liver tissue through disruption of the ultrastructure of mitochondrial membranes and that subsequent regenerative processes may contribute to the promotion of liver tumors (ATSDR 1999a). Other mechanistic hypotheses by which DDT and DDE may promote the development of initiated liver cells include the inhibition of apoptosis (i.e., programmed cell death) and the reduction of gap junctional intercellular communication (ATSDR 1999a).

## C.4 Health Guidelines

ATSDR (1999a) did not derive any MRLs for DDE isomers and did not discuss whether or not the MRLs for DDT (see next paragraph) were applicable to DDE or were restricted to the p,p’-isomers.

ATSDR (1999a) derived an acute oral MRL of 0.002 mg/kg/day and an intermediate oral MRL of 0.007 mg/kg/day for DDT based on a LOAEL of 0.5 mg/kg/day for neurodevelopmental effects in mice exposed to single gavage doses of DDT and a NOAEL of 0.07 for liver effects in rats exposed to DDT in the diet for 15–27 weeks, respectively. ATSDR (1999a) did not derive a chronic oral MRL for DDT due to the inadequacy of available data to describe dose-response relationships for chronic exposures at low dose levels.

IRIS (2001) does not list an RfD or RfC for p,p’-DDE, but lists an RfD of 0.0005 mg/kg/day for p,p’-DDT that was based on a NOAEL of 0.05 mg/kg/day for liver hepatomegaly in rats exposed to 1 ppm commercial DDT in the diet (81% p,p’-isomer and 19% o,p’-isomer). EPA (IRIS 2001) classified p,p’-DDE as a Group B2 compound - probable human carcinogen based on no data on the potential carcinogenicity of p,p’-DDE in humans and sufficient evidence of carcinogenicity from animal studies. Dietary exposure to p,p’-DDE produced increased incidence of liver tumors in two strains of mice and in hamsters and increased incidence of thyroid tumors in female rats. EPA (IRIS 2001) derived an oral slope factor of 0.34 per mg/kg/day based on incidence data for liver tumors in mice and hamsters exposed to p,p’-DDE in the diet, but did not derive a cancer inhalation unit risk estimate for p,p’-DDE.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for oral exposure to p,p’-DDE were derived for endpoints affected by p,p’-DDE and one or more of the other chemicals in the CDD-hexachlorobenzene-DDE-methylmercury mixture that is the subject of this Interaction Profile. The relevant endpoints for p,p’-DDE in this mixture include hepatic, immunological, neurological, reproductive, and developmental effects. Chronic oral TTDs for these endpoints are derived below, using the methods described by ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (1999a), and in particular, the oral LSE table.

Toxicity data for p,p’-DDE are limited (ATSDR 1999a). Far more data are available for the parent p,p’-DDT and for technical DDT, which is 65–80% p,p’-DDT (p,p’-DDE is the primary metabolite and degradation product of p,p’-DDT). Therefore, MRL values derived by ATSDR (1999a) based on studies of p,p’-DDT and technical DDT are expected to be relevant to p,p’-DDE, as are TTD values based on these data.

### Hepatic Effects

ATSDR (1999a) derived an intermediate oral MRL of 0.0007 mg/kg/day for DDT based on a NOAEL of 0.07 and LOAEL of 0.4 mg/kg/day for hepatic effects (cellular hypertrophy, cytoplasmic oxyphilia) in Osborne-Mendel rats fed commercial DDT in the diet for 15–27 weeks (Laug et al. 1950). An uncertainty factor of 100 (10 for extrapolation from rats to humans and 10 to protect sensitive individuals) was applied to the NOAEL to derive the MRL. EPA (IRIS 2001) based the chronic oral RfD for p,p’-DDT (0.0005 mg/kg/day) on the same study. In its derivation, EPA did not use an additional uncertainty factor for extrapolation from subchronic to chronic duration because of a corroborating chronic study by Fitzhugh (1948). This was a 2-year feeding study in rats that reported a LOAEL for liver lesions of 0.5 mg/kg/day (the lowest dose tested). EPA noted that an RfD derived based on this study (0.5 mg/kg/day divided by an uncertainty factor of 1,000) would be identical to that derived by EPA based on the Laug et al. (1950) study, which supports the RfD derivation based on the intermediate-duration study. EPA concluded that the Laug et al. (1950) study was of sufficient duration to observe toxic effects. By the same reasoning, the intermediate oral MRL should be protective for hepatic effects by chronic exposure as well. Therefore, the intermediate oral MRL for DDT of 0.0007 mg/kg/day is adopted as the TTD_HEPATIC_ for p,p’-DDE.

### Immunological Effects

Immune system effects of DDT/DDE have been studied primarily by intermediate exposure (ATSDR 1999a). Chronic studies reported no effects on the thymus, spleen, or lymph nodes at p,p’-DDE doses up to 59 mg/kg/day in rats and 49 mg/kg/day in mice (NCI 1978). However, these studies included only limited evaluation of immune effects (histopathology). Intermediate-duration studies of DDT that have looked at more subtle measures of immune response have reported effects at lower levels. The lowest reliable intermediate LOAEL was reported by Gabliks et al. (1975), who found decreased mast cells and reduced severity of anaphylactic response following challenge with diphtheria toxoid in rats immunized with diphtheria toxoid and fed a diet containing 1.9 mg/kg/day of DDT for 31 days. A NOAEL was not identified. Applying an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from rats to humans, and 10 to protect sensitive individuals) to the LOAEL of 1.9 mg/kg/day yields a TTD_IMMUNO_ of 0.002 mg/kg/day. Due to the sensitivity of the endpoint tested and the large uncertainty factor applied, this TTD may be sufficiently protective to use for chronic exposure.

### Neurological Effects

The nervous system is a well known target for DDT. Doses in excess of 8 mg/kg/day have been reported to produce ataxia, tremors, convulsions, and reduced brain lipid levels in humans and laboratory animals by acute, intermediate, and chronic exposure (ATSDR 1999a). A chronic human NOAEL of 0.61 mg/kg/day for neurological effects was identified in a study by Hayes et al. (1956), in which volunteers were treated with technical DDT at doses up to 0.61 mg/kg/day for 12–18 months. The subjects were observed for tremors and coordination problems, and were given a battery of tests designed to detect peripheral and central nervous system dysfunction. No deficits were identified. A TTD_NEURO_ of 0.06 mg/kg/day can be derived from this chronic human NOAEL by applying an uncertainty factor of 10 to protect sensitive individuals. This TTD is higher, however, than the acute oral MRL of 0.002 mg/kg/day for DDT based on neurodevelopmental effects in mice exposed neonatally (see the section below on developmental effects). Neonatal organisms are considered a sensitive population. Because developmental effects are influenced by timing of dose as well as dose level, it is not clear that a longer exposure period would contribute additionally to the effects. Therefore, it appears reasonable to adopt the acute oral MRL for DDT of 0.002 mg/kg/day as the TTD_NEURO_ for p,p’-DDE.

### Reproductive Effects

The reproductive effects of DDT are reviewed by ATSDR (1999a). The lowest LOAEL identified was for decreased number of implanted ova, lengthening of the estrus cycle, decreased corpora lutea, and decreased implants in female mice exposed to 1.67 mg/kg/day of p,p’-DDT for up to 12 weeks, including premating and gestation (Lundberg 1974). This study did not identify a NOAEL. With the exception of decreased fertility reported at 13 mg/kg/day in one study, chronic multigeneration reproduction studies with DDT (mostly the technical mixture) were negative and reported NOAELs of 0.15–10 mg/kg/day. A TTD_REPRO_ of 0.002 mg/kg/day for p,p’-DDE can be derived from the LOAEL of 1.67 mg/kg/day of p,p’-DDT by applying an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from mice to humans, and 10 to protect sensitive individuals). Because the Lundberg (1974) study included premating and gestational exposure, and because the estimated NOAEL (LOAEL/10) is consistent with the NOAELs reported in multigeneration studies, this TTD is expected to be protective for chronic exposure.

### Developmental Effects

ATSDR (1999a) derived an acute oral MRL of 0.002 mg/kg/day based on developmental effects (increased motor activity) in 10-day-old NMRI mice given a single dose of 0.5 mg/kg/day of technical DDT by gavage (Eriksson and Nordberg 1986). An uncertainty factor of 300 was used (10 for use of a LOAEL, 10 for extrapolation from mice to humans, and 3 to protect sensitive individuals). An uncertainty factor of 3 rather than 10 was used for sensitive individuals because the neonatal mouse was considered to be a sensitive subject. Developmental effects occurred with LOAELs of 16.5–41.3 mg/kg/day and NOAELs of 1.9–8.3 mg/kg/day in chronic studies and with LOAELs of 16.8–84 mg/kg/day and NOAELs of 1.7–16.8 mg/kg/day in intermediate studies. This suggests that the developmental endpoint in the Eriksson and Nordberg (1986) study was more sensitive than those studied by other researchers. Because developmental effects are influenced by timing of dose as well as dose level, it is not clear that a longer exposure period would contribute additionally to the effects observed. Therefore, it appears reasonable to adopt the acute oral MRL for DDT of 0.002 mg/kg/day as the TTD_DEVELOP_ for p,p’-DDE.

### Summary (TTDs for p,p’-DDE)

MRL_(HEPATO)_ = 0.0007 mg/kg/day (7×10^−4^ mg/kg/day)

TTD_IMMUNO_ = 0.002 mg/kg/day (2×10^−3^ mg/kg/day)

TTD_NEURO_ = 0.002 mg/kg/day (2×10^−3^ mg/kg/day)

TTD_REPRO_ = 0.002 mg/kg/day (2×10^−3^ mg/kg/day)

TTD_DEVEL_ = 0.002 mg/kg/day (2×10^−3^ mg/kg/day)