# Appendix B Background Information for Hexachlorobenzene

## B.1 Toxicokinetics

Data from animal studies indicate that absorption of ingested hexachlorobenzene from the gastrointestinal tract is variable, depending on the solvent vehicle used for administration, ranging from about 6% in an aqueous vehicle to up to 82% in oil-based vehicles (ATSDR 1996; Courtney 1979). Inhaled hexachlorobenzene is thought to be poorly absorbed by the respiratory tract (ATSDR 1996). Absorbed hexachlorobenzene is widely distributed in mammalian tissues with preferential distribution to tissues and fluids with high fat content (ATSDR 1996). Hexachlorobenzene is transferred via the placenta to the developing fetus and to suckling neonates via breast milk (ATSDR 1996). In humans, concentrations of hexachlorobenzene tend to increase with age, indicative of bioaccumulation (ATSDR 1996). Absorbed hexachlorobenzene is eliminated from the body predominately as metabolites in the urine, although unchanged hexachlorobenzene has been detected in urine of exposed animals (ATSDR 1996). Data from studies of humans and animals indicate that pentachlorophenol and pentachlorobenzene are the predominant metabolites of hexachlorobenzene, that minor metabolites include tetrachlorobenzene, tetrachlorophenols, chlorinated tetrahydroquinones, trichlorophenol, and derivatives of glutathione conjugates, and that hexachlorobenzene metabolism is slow (ATSDR 1996). Oxidative metabolism of hexachlorobenzene is thought to be catalyzed by cytochrome P450 enzymes (predominately by CYPIIIA1/2), epoxyhydratase, and glutathione transferases; reductive dechlorination of hexachlorobenzene also occurs (ATSDR 1996; den Besten et al. 1993). Hexachlorobenzene induces a wide range of hepatic cytochrome P-450 enzymes including those in the CYPIIIA family (“phenobarbital-inducible”) and the CYP1A1/2 family (“3-methylcholanthrene-inducible”) (Li et al. 1989; Linko et al. 1986).

## B.2 Health Effects

Health effects identified in several studies of people who ingested hexachlorobenzene-contaminated bread in Turkey from 1955 to 1959 include hepatic porphyria, skin lesions (porphyria cutanea tarda) associated with altered heme biosynthesis and accumulation of porphyrins, neurological effects (including muscle weakness and paresthesiae), possible increased risk of fetal toxicity or decreased maternal fertility, and increased frequencies of offspring with dermal scarring and fragile skin, neurological symptoms (paresthesia and weakness), small hands and short stature, and enlarged thyroids (ATSDR 1996; Courtney 1979).

Health effects in animal studies following oral exposure to hexachlorobenzene include hepatomegaly, hepatic degeneration, and hepatic accumulation of porphyrins in rodents; induction of hepatic cytochrome P450 isozymes including CYP1A1/2, CYPIIIA, and CYP2B1, and other hepatic enzyme systems; decreased serum T4 levels, increased serum thyroid stimulating hormone, and enlarged thyroids in rodents; decreased serum levels of corticosterone and cortisol in rodents; increased spleen and lymph node weights and increased susceptibility to certain infectious agents in rodents; electrophysiological changes in the central nervous system of dogs; tremors and muscular weakness in Rhesus monkeys and rodents; alteration of menstrual cycle and degenerative changes of the ovarian follicle in monkeys; altered cellular and humoral immunity capabilities in rodent offspring exposed in utero and during lactation; neurobehavioral deficits in rodents exposed during gestation; decreased survival of monkey and rodent offspring exposed during lactation; and cancer at multiple sites (liver tumors, hemangioendotheliomas and thyroid tumors) in hamsters, rats, and mice (ATSDR 1996; Courtney 1979; Li et al. 1989; Smith et al. 1987).

## B.3 Mechanisms of Action

It has been hypothesized that oxidative metabolism of hexachlorobenzene is required for the development of hexachlorobenzene-induced hepatic porphyria and that the accumulation of uroporphyrin in liver originates from an irreversible inactivation of uroporphyrinogen decarboxylase, a key enzyme in heme synthesis (ATSDR 1996; den Besten et al. 1993). Cotreatment of rats with hexachlorobenzene and TAO, an inhibitor of cytochrome P450IIIA1/2, inhibited urinary porphyrin excretion and hepatic porphyrin accumulation compared with rats exposed to hexachlorobenzene alone (den Besten et al. 1993). den Besten et al. (1993) postulated that uroporphyrinogen decarboxylase is inhibited by an as yet unidentified reactive intermediate that is formed in the liver during the CYPIIIA1/2-catalyzed transformation of hexachlorobenzene to pentachlorophenol. Support for this hypothesis was provided by observations that repeated exposure of rats to high doses of pentachlorobenzene (which is also metabolized to pentachlorophenol and tetrachlorohydroquinone) did not induce porphyria, but increased urinary levels of these metabolites to comparable levels observed in rats treated with porhyria-inducing doses of hexachlorobenzene (den Besten et al. 1993). None of the known hexachlorobenzene metabolites (including pentachlorophenol) is directly porphyrinogenic when administered in vivo. The principal metabolites, pentachlorophenol and tetrachlorohydroquinone (TCHQ), can directly inhibit uroporphyrinogen decarboxylase in vitro, but only at concentrations well above those expected to be reached in liver cells (den Besten et al. 1993).

Sinclair et al. (1997) proposed that the development of hepatic uroporphyria by a number of planar polyhalogenated aromatic hydrocarbons, including CDDs, CDFs, coplanar PCBs, and hexachlorobenzene proceeds by a mechanism that involves the initial induction of CYP1A1 (mediated by interaction with the Ah receptor) which catalyzes the oxidation of uroporphyrinogen to uroporphyrin. The induced increased levels of CYP1A1 are proposed to stimulate uroporphyrin production at the expense of heme production by depleting levels of uroporphyrinogen, the substrate of uroporphyrinogen decarboxylase, and by producing a specific, as yet unidentified, inhibitor of uroporphyrinogen decarboxylase.

It has also been hypothesized that hexachlorobenzene-induced liver tumors develop by a nongenotoxic mechanism involving compensatory hyperplastic responses to hepatocellular damage (see ATSDR 1996).

Hexachlorobenzene-induced disturbances of thyroid homeostasis have been hypothesized to involve changes in thyroid hormone metabolism resulting in increased elimination from the body and/or a mechanism involving interference of plasma thyroxin transport protein by hydroxylated metabolites of hexachlorobenzene such as pentachlorophenol (see den Besten et al. 1993 and van Raaji et al. 1993 for review). Exposure of animals to hexachlorobenzene, PCBs, or dioxins has been shown to decrease total thyroxine and free thyroxine (TT4) levels without affecting total triiodothyronine (TT3) levels (van Raaji et al. 1993). van Raaji et al. (1993) proposed that decreased serum levels of thyroid hormones produced by oral exposure to hexachlorobenzene may be caused via induction, by hexachlorobenzene itself, of enzymes involved in thyroxine catabolism (especially at low exposure levels), and via competitive inhibition of binding of thryroxin to thyroxin-binding serum proteins by hydroxylated metabolites of hexachlorobenzene (e.g., pentachlorophenol).

Information concerning molecular or cellular details of mechanisms whereby hexachlorobenzene causes neurological effects, effects on neurological development, or reproductive effects were not located (ATSDR 1996; Courtney et al. 1979; den Besten et al. 1993; van Raaji et al. 1993).

Although there is an overlap in the types of effects produced by hexachlorobenzene and 2,3,7,8-TCDD (Li et al. 1989; Smith et al. 1987; van Birgelen 1998), the evidence that hexachlorobenzene toxicity is mediated via the Ah receptor is limited and inconclusive. Hexachlorobenzene produced patterns of hepatic CYP induction in Ah-responsive and nonresponsive mouse strains that were consistent with action through the Ah receptor, but the affinity of hexachlorobenzene to bind to the Ah receptor in vitro was 10,000-fold less than that of 2,3,7,8-TCDD (Hahn et al. 1989; Linko et al. 1986).

## B.4 Health Guidelines

ATSDR (1996) did not derive inhalation MRLs for hexachlorobenzene due to inadequate data.

ATSDR (1996) derived an acute oral MRL of 0.008 mg/kg/day based on a LOAEL of 2.5 mg/kg/day for neurobehavioral changes (increased exploratory behavior or slight hyperactivity) in offspring of female rats exposed for 4 days prior to mating with unexposed males and an uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability and 3 for the use of a minimal LOAEL).

ATSDR (1996) derived an intermediate oral MRL of 0.0003 mg/kg/day based on a LOAEL of 0.1 mg/kg/day for reproductive effects (e.g., ultrastructural changes in ovarian epithelial cells indicative of cellular degeneration) in monkeys exposed for 90 days and an uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 for use of a minimal LOAEL).

ATSDR (1996) derived a chronic oral MRL of 0.00002 mg/kg/day based on a LOAEL of 0.016 mg/kg/day for hepatic effects (peribiliary lymphocytosis and peliosis and fibrosis of the liver) in F0 and F1 rats exposed for up to 130 weeks and an uncertainty factor of 1,000 (10 for extrapolation from animals to humans, 10 for human variability, and 10 for use of a LOAEL).

van Birgelen (1998) recently proposed that hexachlorobenzene should be classified as a dioxin-like compound because it binds (competitively with 2,3,7,8-TCDD, albeit with much less affinity) to the Ah receptor, it causes a range of effects in mammals similar to those of other dioxin-like compounds (induction of CYP1A1/2, hepatic porphyria and degenerative effects, changes in thyroid hormone levels and metabolism, reproductive effects, developmental effects, and immunological effects), and it bioaccumulates. van Birgelen (1998) proposed that a relative potency value of 0.0001 be used for hexachlorobenzene based on in vitro observations that hexachlorobenzene had a binding affinity to the rat Ah receptor that was about 10,000-fold less than 2,3,7,8-TCDD’s affinity (Hahn et al. 1989) and had an ability to induce ethoxyresorufin O-deethylase (a CYP1A activity) in chicken hepatocytes that was 5,000- to 10,000-fold less than the induction activity of 2,3,7,8-TCDD (Sinclair et al. 1997). Systemic and cancer health effects from hexachlorobenzene, however, can be evaluated separately without having to include it in the TEF approach. It may be preferable to evaluate hexachlorobenzene health effects outside of the TEF approach, because the health effect data on hexachlorobenzene are sufficient for the derivation of a slope factor and MRLs (as noted above), and support for inclusion of hexachlorobenzene in the TEF approach is limited to the in vitro data showing that it binds to the Ah receptor with an affinity that is 10,000-fold less than TCDD.

EPA (IRIS 2001) derived a chronic oral Reference Dose (RfD) of 0.0008 mg/kg/day based on a NOAEL of 0.08 mg/kg/day for liver effects in F0 and F1 rats exposed to hexachlorobenzene in the diet for up to 130 weeks (the LOAEL was 0.29 mg/kg/day) and an uncertainty factor of 100 (10 for interspecies variability and 10 for intraspecies variability). EPA (IRIS 2001) noted that data were inadequate for Reference Concentration (RfC) derivation.

EPA (IRIS 2001) classified hexachlorobenzene as a Group B2 compound - probable human carcinogen, based on inadequate evidence of cancer in studies of hexchlorobenzene-exposed humans and sufficient evidence of cancer in studies of rats, hamsters, and mice exposed to hexachlorobenzene in the diet. EPA (IRIS 2001) noted that the animal data indicate that the liver appears to be the primary target organ for hexachlorobenzene-induced cancer, and that neoplasms of the thyroid and kidney also have been observed. An oral slope factor of 1.6 per (mg/kg)/day was derived based on incidence of hepatocellular carcinomas in female rats exposed to hexachlorobenzene in the diet and a linearized multistage extrapolation method (IRIS 2001). An inhalation unit risk of 4.6×10^−4^ per µg/m^3^ was calculated based on the female rat liver tumor data from the dietary study.

## B.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for oral exposure to hexachlorobenzene were derived for endpoints affected by hexachlorobenzene and one or more of the other chemicals in the CDD-hexachlorobenzene-DDE-methylmercury mixture that is the subject of this Interaction Profile. The relevant endpoints for hexachlorobenzene in this mixture include hepatic, endocrine, immunological, neurological, reproductive, and developmental effects. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (1999a, Section 2.3.2). The derivations are based on data provided in ATSDR (1996), and in particular, the oral LSE table.

### Hepatic Effects

ATSDR (1996) derived a chronic oral MRL of 0.00002 mg/kg/day for hexachlorobenzene based on a LOAEL of 0.016 mg/kg/day for hepatic effects (peribiliary lymphocytosis and peliosis and fibrosis of the liver) in F0 and F1 rats exposed for up to 130 weeks and an uncertainty factor of 1,000 (10 for extrapolation from animals to humans, 10 for human variability, and 10 for use of a LOAEL).

### Endocrine Effects

Endocrine effects were not reported in chronic studies. However, intermediate studies reported a number of endocrine effects, including effects on the thyroid, parathyroid, and adrenal glands, primarily at doses of 10–1000 mg/kg/day (ATSDR 1996). The lowest endocrine LOAELs were 5 mg/kg/day (with a NOAEL of 0.5 mg/kg/day) for increased thyroid weight in a 90-day feeding study in pigs (Den Tonkelaar et al. 1978) and 1 mg/kg/day (with a NOAEL of 0.1 mg/kg/day) for increased serum levels of parathyroid hormone in rats treated with hexachlorobenzene by daily gavage for 15 weeks (Andrews et al. 1989). Applying an uncertainty factor of 100 (10 for extrapolation from rats to humans and 10 to protect sensitive individuals) to the NOAEL of 0.1 mg/kg/day for serum parathyroid hormone changes yields a TTD_ENDOCRINE_ of 0.001 mg/kg/day for hexachlorobenzene. Although based on an intermediate study, this TTD may be protective for chronic exposure as well due to the sensitive nature of the endpoint tested.

### Immunological Effects

Data regarding the immune effects of hexachlorobenzene are reported by ATSDR (1996). The only chronic study reported a LOAEL of 0.12 mg/kg/day for hyperplasia of lymphoid tissue in the stomach in dogs exposed for one year (Gralla et al. 1977). Acute and intermediate studies reported effects (increased susceptibility to infection, reduced antibody production, increased lymphocyte count, and thymic atrophy) at doses of 8 mg/kg/day or more. A TTD_IMMUNO_ of 0.0004 mg/kg/day can be derived by applying an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for extrapolation from dogs to humans, and 10 to protect sensitive individuals) to the chronic LOAEL of 0.12 mg/kg/day.

### Neurological Effects

Overt neurological effects (e.g., lethargy, ataxia, tremors, convulsions and paralysis) occurred at 16 mg/kg/day in rats chronically exposed to hexachlorobenzene and at doses of 32 mg/kg/day and above in intermediate-duration studies (ATSDR 1996). Electrophysiological changes (e.g., reduced conduction velocity) were reported at 3.75 mg/kg/day in a 2-year rat study (Sufit et al. 1986), but this study was apparently not considered reliable by ATSDR (1996). The lowest LOAEL for a neurological effect was 0.4 mg/kg/day for an increase in brain weight in rats in a 90-day feeding study. The NOAEL for this effect was 0.08 mg/kg/day. Although not of chronic duration, this NOAEL may be suitable for TTD derivation because it is based on a sensitive endpoint, and is well below the NOAELs reported in chronic studies (5–120 mg/kg/day). A TTD_NEURO_ of 0.0008 mg/kg/day can be derived by applying an uncertainty factor of 100 (10 for extrapolation from rats to humans and 10 to protect sensitive individuals) to the NOAEL of 0.08 mg/kg/day.

### Reproductive Effects

ATSDR (1996) derived an intermediate oral MRL for hexachlorobenzene of 0.0003 mg/kg/day based on a LOAEL of 0.1 mg/kg/day for reproductive effects (e.g., ultrastructural changes in ovarian epithelial cells indicative of cellular degeneration) in monkeys exposed for 90 days and an uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 for use of a minimal LOAEL). No chronic studies were located that investigated reproductive endpoints. In the absence of chronic data, the intermediate MRL of 0.0003 mg/kg/day, which is based on a sensitive endpoint, is suitable.

### Developmental Effects

ATSDR (1996) derived an acute oral MRL of 0.008 mg/kg/day for hexachlorobenzene based on a LOAEL of 2.5 mg/kg/day for developmental neurotoxicity and an uncertainty factor of 300 (10 for extrapolation from animals to humans, 10 for human variability, and 3 for the use of a minimal LOAEL). LOAELs for developmental effects in intermediate and chronic studies ranged from 2 to 64 mg/kg/day (excluding liver effects in multigeneration studies, which were considered hepatic rather than developmental effects). Therefore, the acute oral MRL of 0.008 mg/kg/day should be protective for developmental effects by longer-term exposure as well, and is adopted as the TTD_DEVELOP_ for hexachlorobenzene.

### Summary (TTDs for hexachlorobenzene)

MRL_(HEPATIC)_ = 0.00002 mg/kg/day (2×10^−5^ mg/kg/day; chronic MRL)

TTD_ENDOCRINE_ = 0.001 mg/kg/day (1×10^−3^ mg/kg/day)

TTD_IMMUNO_ = 0.0004 mg/kg/day (4×10^−4^ mg/kg/day)

TTD_NEURO_ = 0.0008 mg/kg/day (8×10^−4^ mg/kg/day)

MRL_(REPRO)_ = 0.0003 mg/kg/day (3×10^−4^ mg/kg/day; intermediate MRL)

TTD_DEVELOP_ = 0.008 mg/kg/day (8×10^−3^ mg/kg/day)