# Appendix A Background Information for Chlorinated Dibenzo-p-Dioxins (CDDs)

## A.1 Toxicokinetics

Results from studies of humans and animals given oral doses of 2,3,7,8-TCDD and other CDDs indicate that ingested CDDs can be well absorbed, that the efficiency of gastrointestinal can be influenced by vehicle (i.e., absorption efficiencies are less for CDDs ingested with soil compared with CDDs ingested with an oil vehicle), and that CDDs with higher chlorination (e.g., octa-CDDs) are poorly absorbed compared with less chlorinated CDDs such as tetra-CDDs (ATSDR 1998). Inhalation and dermal exposure to CDDs are of lesser concern than oral exposure (because ingestion of CDDs in food is thought to be the principal route of exposure for the general population), but limited information from exposed human and animal studies indicate that CDDs can be absorbed by these routes. Information from studies of exposed humans and laboratory animals indicates that absorbed CDDs are distributed preferentially to fatty tissues and to a lesser extent, the liver (ATSDR 1998). CDDs can be transferred to the fetus across the placenta and to nursing infants via breast milk. CDDs are slowly metabolized in mammalian tissues via oxidation and reductive dechlorination reactions catalyzed by cytochrome P450 enzymes, followed by conjugation to more polar molecules such as glutathione and glucuronic acid (ATSDR 1998). The metabolism of 2,3,7,8-TCDD and related compounds is required for urinary and biliary excretion, and the rate of metabolism is thought to play a major role in regulating the rate of elimination (and detoxification) of these compounds (Van den Berg et al. 1994). The major routes of excretion of CDDs are via the bile and feces, whereas smaller amounts are excreted via the urine (ATSDR 1998). Monitoring of nursing mothers indicates that lactation can be a significant route of elimination of CDDs (ATSDR 1998). Results from studies of animals and humans exposed to 2,3,7,8-TCDD and related compounds indicate that CDDs and CDFs are slowly eliminated from the body; reported half-lives ranged from about 1–9 years in humans, close to a year in monkeys, and 10–100 days in laboratory rodents (ATSDR 1998; Van den Berg et al. 1994). Because of the long-half life of most of the halogenated aromatic hydrocarbons, animals or humans will be exposed for relatively long periods of time following single exposures.

## A.2 Health Effects

Exposure to CDDs such as 2,3,7,8-TCDD and related halogenated aromatic hydrocarbons have been associated with a range of toxic effects that include (ATSDR 1999b; Devito and Birnbaum 1994):

1. a wasting syndrome that develops slowly in animals following acute lethal doses and body weight decreases following sublethal doses;
2. thymic atrophy in adult and developing animals following administration of nonlethal doses (the developing thymus is affected at lower doses than the adult thymus, and affected juvenile animals also show immune suppression);
3. chloracne in humans and animals following dermal or systemic exposure;
4. hepatic hyperplasia and hepatomegaly accompanied with degenerative lesions (including uroporphyrin accumulation) in certain animal species following repeated exposure and liver dysfunction in some humans immediately following acute high-dose exposures;
5. decreased nerve conduction velocity and histological signs of nerve degeneration in rats exposed to intraperitoneal doses of 2,3,7,8-TCDD (2.2–8.8 µg/kg);
6. suppression of humoral and cell-mediated immunity with accompanying increased susceptibility to infectious agents in mice following administration of low doses (as low as a single 2,3,7,8-TCDD dose of 10 ng/kg);
7. decreased serum or plasma levels of the thyroid hormone, thyroxin (T4), in rodents following acute (0.1–0.3 µg/kg) or subchronic (0.05–0.8 µg/kg) oral exposure to 2,3,7,8-TCDD presumably involving TCDD-induction of UDP-glucuronyltransferase which catalyzes the metabolism of T4;
8. estrogenic effects (from 2,3,7,8-TCDD) including reduced fertility, litter size, and uterine weights, and suppression of the estrous cycle in adults of several animal species (these effects occur at doses that alter body weights in some species, and at doses without overt toxicity in other species);
9. altered development of female reproductive tissues following perinatal exposure of mice;
10. antiandrogenic effects including loss of germ cells, degeneration of spermatocytes and spermatozoa, and decreased reproductive capability in males of several animal species following exposure to doses producing overt toxicity such as decreased food intake and body weight, and decreased serum testosterone levels, increased serum folloicle-stimulating hormone, and increased luteinizing hormone in male workers exposed to 2,3,7,8-TCDD during manufacture of 2,4,5-trichlorophenol;
11. impaired development of male reproductive tissues and impaired sexual behavior in male adult rats who experienced in utero exposure from single doses of 2,3,7,8-TCDD as low as 0.064 µg/kg given on gestation day 15;
12. cleft palate and hydronephrosis in mice following in utero exposure to doses that did not produce other fetal or maternal toxic effects, and other malformations in other animal species at doses that produced maternal toxicity;
13. ectodermal dysplasia, neurobehavioral abnormalities, and delays in developmental milestones in offspring of women exposed to mixtures of CDFs and PCBs including dioxin-like and non-dioxin-like PCBs;
14. neurobehavioral effects in offspring of monkeys exposed during the mating period, gestation, and lactation; and
15. cancer, at multiple sites (e.g., liver, thyroid, lung) in a number of animal species following oral exposure to 2,3,7,8-TCDD.

## A.3 Mechanisms of Action

CDDs, CDFs, and dioxin-like PCBs produce a wide spectrum of biochemical effects in mammals that include induction of phase I enzymes (most notably CYP1A1 and CYP1A2) and phase II enzymes (e.g., UDP-glucuronosyl transferase and glutathione-S-transferase), reduction of levels of several growth factors (epidermal growth factor [EGF], transforming growth factor [TGF]-α, and TGF-β1) and increased expression of EGF receptor, and changes in thyroid hormone metabolism leading to lowered thyroid hormone levels (ATSDR 1998; Devito and Birnbaum 1994; Van den Berg et al. 1994). Many of the toxic and biological responses to CDDs, CDFs, and dioxin-like PCBs are thought to be initially mediated through the binding of the parent compounds to a soluble intracellular protein, the Ah receptor (ATSDR 1998; Devito and Birnbaum 1994; Van den Berg et al. 1994). The ligand-receptor complex is thought to be transported to the nucleus where it interacts with deoxyribonucleic acid (DNA) and alters gene expression. For example, the induction of CYP1A1 by 2,3,7,8-TCDD is thought to be due to the interaction of the TCDD-Ah receptor complex with nuclear genetic material leading to increased expression of the CYP1A1 gene (ATSDR 1998).

Alterations in gene expression have been linked to the development of some of the specific toxic responses to 2,3,7,8-TCDD and related compounds. General evidence that the Ah receptor mediates the toxicity of CDDs, CDFs, and related PCBs comes from demonstrations that the toxicity of specific congeners is related to the affinity with which the compounds bind to the Ah receptor and demonstrations that genetic differences in Ah receptor binding affinity between strains of rodents are related to genetic differences in responsiveness to the toxic or biochemical effects of TCDD (Okey et al. 1994).

A working hypothesis of the molecular mechanism by which 2,3,7,8-TCDD induces cleft palate formation in rodents has received considerable research attention and illustrates how toxic effects may be mediated by CDDs, CDFs, and PCBs through the Ah receptor. In this mechanistic scheme, the TCDD-Ah receptor’s transcriptional regulation of gene expression is thought to indirectly lead to reduced levels of several growth factors (EGF, TGF-α, and TGF-β1) and increased expression of the EGF receptor, which subsequently lead to altered medial cell proliferation in the developing palatal shelves (Abbott et al. 1994). TCDD-induced disruptions in the development of the kidney and male and female reproductive organs, observed in animal experiments, are also thought to be associated with TCDD-induced changes in levels of growth factors and receptors (ATSDR 1998). The molecular events between TCDD-induced changes in gene expression and reduced levels of growth factors remain to be elucidated (ATSDR 1998).

A proposed mechanistic hypothesis for hepatic porphyria and liver damage induced by a number of halogenated aromatic hydrocarbons provides another illustration of how the Ah receptor is thought to mediate toxicity (Sinclair et al. 1997). In this hypothesis, the ligand-Ah receptor complex initially increases the expression of the CYP1A1 gene. The increased levels of CYP1A1 enzymic activity are thought to stimulate uroporphyrin oxidation from uroporphyrinogen by producing a specific, as yet unidentified, inhibitor of uroporphyrinogen decarboxylase (which is the initial step in heme synthesis from uroporphyrinogen) and by depleting levels of uroporphyrinogen, the substrate of uroporphyrinogen decarboxylase. Increased levels of reactive products of CYP1A1-catalyzed oxidation of xenobiotics may also be involved in the production of the liver damage observed after exposure to halogenated aromatic hydrocarbons.

Results from studies of animals exposed for acute or subacute periods indicate that CDDs, such as 2,3,7,8-TCDD, and related halogenated aromatic hydrocarbons suppress immunological responses to various substances (e.g., tuberculin, sheep red blood cells) or resistance to bacterial, parasitic, viral, or neoplastic disease at doses well below those that cause lymphoid tissue depletion (e.g., atrophy of the thymus) (Kerkvliet 1994). Involvement of the Ah receptor in halogenated aromatic hydrocarbon immunotoxicity has been established by results from studies with CDDs, CDFs, and PCB congeners with differing binding affinity to the Ah receptor and studies using mice strains that differ genetically at the Ah locus, but the critical target cells and tissues and the molecular events involved in the immunosuppresive effects of 2,3,7,8-TCDD and other halogenated aromatic hydrocarbons remain to be elucidated (see Kerkvliet 1994 for review).

Changes in serum T4 levels from acute exposure to 2,3,7,8-TCDD has been postulated to involve TCDD induction of UDP-glucuronyltransferase, through the Ah receptor, and subsequently increased metabolism and clearance of T4 (ATSDR 1998; Weber et al. 1995). From a comparison of responses to acute exposure to 2,3,7,8-TCDD among rats and different genetic strains of mice, however, Weber et al. (1995) have proposed that the Ah receptor may not be the sole mediator of the toxicity of 2,3,7,8-TCDD. It has been postulated that some aspects of TCDD-disruption of thyroid hormone homeostasis may involve actions not related to Ah receptor mediation, such as interference, by TCDD metabolites, of T4 binding to plasma transport proteins (ATSDR 1998).

Carcinogenic responses to 2,3,7,8-TCDD are thought to not involve direct damage to DNA by TCDD or its metabolites, but have been proposed to involve Ah-receptor-mediated increased formation of DNA-damaging oxidative species from other exogenous and endogenous agents and Ah-receptor-mediated disruption of cellular differentiation and/or division (ATSDR 1998). Mechanistic details at the cellular and molecular level are poorly understood.

## A.4 Health Guidelines

Because humans are exposed to complex and varying mixtures of CDDs and other halogenated aromatic hydrocarbons such as CDFs and PCBs and because there are limited toxicological data for these complex mixtures and most of their components, a Toxic Equivalency Factor (TEF) approach has been adopted to assess the health risks from exposure to these complex mixtures (ATSDR 1998). This approach assumes that components of concern (i.e., CDDs and CDD-like congeners) induce toxic effects through a common initial mechanism mediated by interaction with the Ah receptor and that the doses are additive (i.e., there are no synergistic or antagonistic interactions among the components of the mixture that interact with the Ah receptor). Carcinogenic, immunotoxic, developmental, and reproductive effects from CDDs and CDD-like compounds are generally thought to be mediated through the Ah receptor (ATSDR 1998). The TEF approach compares the relative potency of individual congeners, based on in vitro or acute in vivo data, with that of 2,3,7,8-TCDD, the best-studied member of this chemical class, so that the TEF for 2,3,7,8-TCDD is 1. The concentration or dose of each active component in the mixture of concern is multiplied by its TEF to arrive at a TEQ, and the TEQs are added to give the total toxic equivalency of the mixture. The hazard or risk presented by exposure to the mixture can be assessed by comparing the mixture total TEQ (in units of mg/kg/day) with an MRL for 2,3,7,8-TCDD or by multiplying the TEQ (in appropriate units) by a cancer slope factor for 2,3,7,8-TCDD (ATSDR 1999a). TEFs have recently been recommended by the World Health Organization for 7 CDD, 10 CDF, and 12 PCB congeners (Van den Berg et al. 1998).

ATSDR (1998) adopted a policy to use MRLs derived for 2,3,7,8-TCDD for other dioxin-like compounds, expressed in total TEQs.

ATSDR (1998) has derived MRLs for acute-, intermediate-, and chronic-duration oral exposure to 2,3,7,8-TCDD.

The acute MRL of 0.0002 µg/kg/day was based on a no-observed-adverse-effect-level (NOAEL) of 0.005 µg/kg/day and a lowest-observed-adverse-effect level (LOAEL) of 0.01 µg/kg for immunological effects (increased susceptibility to influenza A-induced mortality) in mice given single gavage doses of 2,3,7,8-TCDD and an uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability).

The intermediate MRL of 0.00002 µg/kg/day was based on a NOAEL of 0.0007 µg/kg/day and a LOAEL of 0.005 µg/kg/day for immunological effects (decreased thymus weight) in guinea pigs fed 2,3,7,8-TCDD in the diet for 90 days and an uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability).

The chronic MRL of 0.000001 µg/kg/day was based on a LOAEL for neurobehavioral effects (changes in social behavior in offspring) following the exposure of female monkeys to 2,3,7,8-TCDD in the diet throughout the mating period, gestation, and lactation and an uncertainty factor of 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR (1998) concluded that the results of epidemiology and animal studies indicate that 2,3,7,8-TCDD may be a human carcinogen. International Agency Research on Cancer (IARC) (1997) classified 2,3,7,8-TCDD as a Group 1 compound - human carcinogen, based on limited evidence in humans and sufficient evidence in animals for the carcinogenicity of 2,3,7,8-TCDD. IARC (1997) considered the following in making this evaluation: “(i) 2,3,7,8-TCDD is a multi-site carcinogen in experimental animals that has been shown by several lines of evidence to act through a mechanism involving the Ah receptor; (ii) this receptor is highly conserved in an evolutionary sense and functions the same way in humans as in experimental animals; (iii) tissue concentrations are similar both in heavily exposed human populations in which an increased overall cancer risk was observed and in rats exposed to carcinogenic dosage regimens in bioassays”. IARC (1997) also concluded that “other polychlorinated dibenzo-p-dioxins are not classifiable as to their carcinogenicity to humans (Group 3)”, based on inadequate evidence in humans and animals. The EPA Integrated Risk Information System (IRIS) does not list a weight-of-evidence classification for 2,3,7,8-TCDD or other CDDs, but EPA (1997a) concluded, in a proposed rule to add “dioxin and dioxin-like compound” to the list of chemicals subject to release reporting requirements, that “based on the EPA weight of evidence classification criteria, there is sufficient evidence to conclude that 2,3,7,8-TCDD is a probable human carcinogen”. Quantitative cancer risk estimates for CDDs were not derived by EPA in the proposed ruling (EPA 1997a) and are not available on IRIS (IRIS 2001). However, the EPA (1997b) Health Effects Assessment Summary Table lists an oral slope factor of 150,000 per mg/kg/day for 2,3,7,8-TCDD that was based on respiratory and liver tumor incidence for rats exposed to 2,3,7,8-TCDD in the diet.

## A.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to 2,3,7,8-TCDD were derived for endpoints affected by 2,3,7,8-TCDD and one or more of the other chemicals in the CDD-hexachlorobenzene-DDE-methylmercury mixture that is the subject of this Interaction Profile. The relevant endpoints for 2,3,7,8-TCDD in this mixture include hepatic, endocrine, immunological, neurological, reproductive, and developmental effects. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (1999a, Section 2.3.2). The derivations are based on data provided in ATSDR (1998), and in particular, the oral Levels of Significant Exposure (LSE) table.

### Hepatic Effects

Numerous studies have observed liver effects in laboratory animals exposed to 2,3,7,8-TCDD for acute, intermediate, and chronic durations (ATSDR 1998). The lowest LOAEL for hepatic effects in a chronic study was reported by Kociba et al. (1978). Sprague-Dawley rats exposed daily to 2,3,7,8-TCDD in the feed for 2 years were found to have liver lesions, including cytoplasmic vacuolation, hyperplasia, hepatocellular degeneration, and liver necrosis, at doses as low as 0.001 µg/kg/day in females and 0.01 µg/kg/day in males. Hepatic necrosis was reported to be severe and extensive at 0.01 µg/kg/day. A NOAEL was not identified.

Chronic studies by NTP (1982) in Osborne-Mendel rats and B6C3F_1_ mice generally support the findings of Kociba et al. (1978). The studies reported toxic hepatitis (liposis and hydropic degeneration of hepatocytes with proliferation of bile ductules and mild fibrosis) in both species with chronic 2-year exposure. For both species, the LOAEL was 0.07 µg/kg/day and the NOAEL was 0.007 µg/kg/day. The NOAEL of 0.007 µg/kg/day in the NTP study is not consistent with the LOAEL of 0.001 µg/kg/day in the Kociba study, but this may be an artifact of the dosing schedule in the NTP study, in which the animals were given 2,3,7,8-TCDD twice a week by gavage (rather than daily in the feed). The intermediate duration studies also support the Kociba et al. (1978) results; the lowest intermediate hepatic LOAEL was 0.005 µg/kg/day for 90 day dietary exposure in guinea pigs (DeCaprio et al. 1986).

A TTD_HEPATIC_ can be derived for 2,3,7,8-TCDD by applying an uncertainty factor (UF) of 300 (10 for use of a LOAEL, 3 for extrapolation from rats to humans, and 10 to protect sensitive individuals) to the chronic hepatic LOAEL of 0.001 µg/kg/day from the Kociba et al. (1978) study. This yields a TTD_HEPATIC_ of 0.000003 µg/kg/day. The use of an uncertainty factor of 3 rather than 10 for extrapolation from rats to humans follows the MRL derivations in ATSDR (1998) and is based on a comparison of sensitivity to 2,3,7,8-TCDD among animal species.

### Endocrine Effects

Thyroid effects of 2,3,7,8-TCDD have been well studied, albeit primarily by acute and intermediate exposure (ATSDR 1998). Chronic studies reported no effects on the thyroid at doses up to 0.07–0.1 µg/kg/day in rats and 0.3 µg/kg/day in mice (Kociba et al. 1978; NTP 1982). However, these studies included only limited evaluation of thyroid effects (histopathology). Intermediate-duration studies that have looked at thyroid hormone levels have reported effects at lower levels. The lowest LOAEL was reported by Li and Rozman (1995), who found a 50% decrease in serum T4 in male Sprague-Dawley rats treated with 0.03 µg/kg/day of 2,3,7,8-TCDD by gavage in oil once per week for 10 weeks, with a NOAEL of 0.003 µg/kg/day. Applying an uncertainty factor of 30 (3 for extrapolation from rats to humans and 10 to protect sensitive individuals) to the NOAEL of 0.003 µg/kg/day yields a TTD_ENDOCRINE_ of 0.0001 µg/kg/day. A 13-week feeding study in rats identified a NOAEL of 0.026 µg/kg/day and a LOAEL of 0.047 µg/kg/day for reduced serum T4 (Van Birgelen et al. 1995). Although chronic studies have not adequately studied the thyroid, the result in the 13-week feeding study suggests that a TTD based on Li and Rozman (1995) may be adequately protective for thyroid effects by long-term dietary exposure.

### Immunological Effects

The immune system is a sensitive target for 2,3,7,8-TCDD in animal studies. Both the acute oral MRL of 0.0002 µg/kg/day (immunosuppression) and the intermediate oral MRL of 0.00002 µg/kg/day (thymic atrophy) for 2,3,7,8-TCDD are based on immunological effects (ATSDR 1998). The lowest LOAEL for immunological effects in a chronic study was 0.002 µg/kg/day for bone marrow and lymphoid tissue degeneration in Rhesus monkeys exposed to 2,3,7,8-TCDD daily in the diet for up to 33 months (Hong et al. 1989). Monkeys exposed to 0.001 µg/kg/day in the same experiment did not have immune effects (Hong et al. 1989). Applying an uncertainty factor of 30 (3 for extrapolation from monkeys to humans and 10 for protection of sensitive individuals) to the NOAEL of 0.001 µg/kg/day would lead to a TTD_IMMUNO_ of 0.00003 µg/kg/day, which is slightly higher than the intermediate oral MRL (0.00002 µg/kg/day) based on immunological effects. This occurs because the intermediate oral MRL is based on a LOAEL of 0.005 µg/kg/day for thymic atrophy in a 90-day feeding study in guinea pigs (DeCaprio et al. 1986), which is consistent with the chronic data, but a NOAEL of 0.0007 µg/kg/day, which is slightly lower than the chronic NOAEL. Because the intermediate NOAEL on which the intermediate oral MRL is based (0.0007 µg/kg/day) is well below the chronic LOAEL (0.002 µg/kg/day) and also below the chronic NOAEL (0.001 µg/kg/day), the intermediate oral MRL also should be protective for immunological effects by chronic exposure.

### Neurological Effects

The chronic MRL of 0.000001 µg/kg/day was based on a LOAEL for neurobehavioral effects (changes in social behavior in the offspring) following the exposure of female monkeys to 2,3,7,8-TCDD in the diet throughout the mating period, gestation, and lactation and an uncertainty factor of 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability). Because this MRL is based on neurological effects in a sensitive population (developing fetuses and neonates), it should be protective for neurological effects in other individuals as well.

### Reproductive Effects

Reproductive effects have been widely reported in animals exposed to 2,3,7,8-TCDD (ATSDR 1998). The lowest LOAEL for reproductive effects was for the development of endometriosis in Rhesus monkeys 10 years after the end of a 4-year exposure period during which the monkeys received 2,3,7,8-TCDD in the feed daily. The incidence and severity of the effect were dose-related, with a LOAEL of 0.00012 µg/kg/day (Rier et al. 1993). These are the same monkeys that were used in the developmental study upon which the chronic oral MRL is based. ATSDR (1998) considered using the reproductive LOAEL of 0.00012 µg/kg/day as the basis for the oral MRL. An uncertainty factor of one for extrapolation from monkeys to humans was proposed by ATSDR (1998) because monkeys appear to be more sensitive to endometriosis than humans (30% background incidence in monkeys and 10% background incidence in humans), along with uncertainty factors of 10 for use of a LOAEL and 10 to protect sensitive individuals. Applying these uncertainty factors (total UF = 100) to the LOAEL of 0.00012 µg/kg/day yields a TTD_REPRO_ of 0.000001 µg/kg/day for 2,3,7,8-TCDD, which is the same as the chronic oral MRL.

### Developmental Effects

As described under neurological effects above, the chronic oral MRL for 2,3,7,8-TCDD (ATSDR 1998) is based on neurodevelopmental effects (changes in social behavior in offspring of monkeys exposed during the mating period, gestation, and lactation). Thus, the chronic oral MRL of 0.000001 µg/kg/day for 2,3,7,8-TCDD is suitable to assess the potential for developmental effects.

### Summary (TTDs for 2,3,7,8-TCDD)

TTD_HEPATIC_ = 0.000003 µg/kg/day (3×10^−6^ µg/kg/day; 3×10^−9^ mg/kg/day)

TTD_ENDOCRINE_ = 0.0001 µg/kg/day (1×10^−4^ µg/kg/day; 1×10^−7^ mg/kg/day)

TTD_REPRO_ = 0.000001 µg/kg/day (1×10^−6^ µg/kg/day; 1×10^−9^ mg/kg/day )

MRL_(IMMUNO)_ = 0.00002 µg/kg/day (2×10^−5^ µg/kg/day; 2×10^−8^ mg/kg/day; intermediate MRL)

MRL_(NEURODEVELOP)_ = 0.000001 µg/kg/day (1×10^−6^ µg/kg/day; 1×10^−9^ mg/kg/day; chronic MRL)