# SUMMARY

Breast-feeding offers the developing infant the benefits of balanced nutrition and passive immunization, but the detection of persistent, environmental chemicals in human breast milk samples from various regions of the world has led to concerns that these chemicals may have detrimental effects on the health and/or development of children. Chlorinated dibenzo-p-dioxins (CDDs), hexachlorobenzene, p,p’-DDE, methylmercury, and polychlorinated biphenyls (PCBs) were selected as an important subset of persistent chemicals detected in breast milk for the purposes of reviewing data on their joint toxic actions following oral exposure.

Epidemiological studies in Michigan, North Carolina, New York, the Netherlands, and the Faroe Islands found statistically significant associations between increasing concentrations of particular persistent chemicals found in maternal fluid samples (i.e., PCBs, CDDs, p,p’-DDE, or mercury in cord serum or breast milk) and deficits in motor and cognitive functions in children. The Netherlands and Faroe Islands studies also demonstrated beneficial effects of breast feeding on neurological development. A study of formula-fed monkeys exposed to a PCB mixture from birth to 20 weeks found evidence that lactational exposure to persistent chemicals may contribute to neurodevelopmental deficits. These studies identify mild neurodevelopmental deficits as a possible health hazard, but the results are suggestive that observed deficits may have been associated with gestational rather than lactational exposure to persistent chemicals. These studies do not establish causal relationships between exposure to persistent chemicals in breast milk and neurological deficits. Furthermore, they are not useful for assessment of health hazards specific to a community or scenarios involving exposures to mixtures of CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs.

To facilitate exposure-based assessments of possible health effects associated with oral exposures to mixtures of CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs in environmental media, food, and/or breast milk, available data on the joint toxic action of mixtures of these breast milk contaminants were reviewed, and the weights of evidence were assessed concerning the mode of joint toxic action of pairs of the five chemicals. Only a limited amount of evidence is available on the existence of greater-than-additive or less-than-additive interactions between a few pairs of the chemicals of concern: (1) hexachlorobenzene potentiation of tetrachlorodibenzo-p-dioxin (TCDD) reduction of body and thymus weights (a greater-than-additive interaction); (2) PCB antagonism of TCDD immunotoxicity (less-than-additive interaction); (3) PCB antagonism of TCDD developmental toxicity (less-than-additive interaction); and (4) synergism between PCBs and methylmercury in disrupting regulation of brain levels of dopamine that may influence neurological function and development (greater-than-additive interaction). Weight-of-evidence analyses of these data, however, indicate that scientific evidence for these interactions is limited and is inadequate to characterize the possible modes of joint action on these toxicity targets. For the remaining pairs, additive joint action at shared targets of toxicity is either supported by data (for a few pairs) or is recommended as a public health protective assumption due to lack of interaction data, conflicting interaction data, and/or lack of mechanistic understanding to reliably project potential non-additive interactions. Therefore, it is recommended that additivity be assumed as a public health protective measure in exposure-based assessments of health hazards from exposure to mixtures of these components.

A target-organ toxicity dose (TTD) modification of the hazard index approach is recommended for carrying out exposure-based screening assessments of possible health effects from oral exposure to mixtures of the chemicals. TTDs for the individual chemical components are derived, and application of the approach is described. There are several reasons supporting this recommendation to use a component-based approach. There are no direct data available to characterize health hazards (and dose-response relationships) from mixtures containing all five components. Physiologically-based pharmacokinetic/pharmacodynamic (PBPK/PD) models have not yet been developed that would predict pertinent target doses of the components under scenarios involving exposure to mixtures of all five components. Finally, available information on toxic actions of the individual components indicates that joint actions of CDDs, hexachlorobenzene, p,p’-DDE, methylmercury, and PCBs on several toxicity targets are plausible, including nervous system development, immune functions, reproductive organ development, and cancer. If the screening assessment indicates a potential hazard to public health, further evaluation is needed, using biomedical judgment and community-specific health outcome data, and taking into account community health concerns.