# Appendix D Background Information for Methylmercury

## D.1 Toxicokinetics

Results from studies with humans and laboratory animals indicate that methylmercury and its salts (e.g., methylmercuric chloride and methylmercuric nitrate) are readily and completely absorbed by the gastrointestinal tract, but quantitative information on absorption of methylmercury by the respiratory tract is not available (ATSDR 1999b). Absorbed methylmercury is widely distributed among tissues with the kidney showing the highest accumulation of mercury. Mercury from methylmercury can also accumulate in the brain and fetus due to methylmercury’s abilities to penetrate the blood-brain and placental barriers and its conversion in the brain and fetus to the inorganic divalent cation (ATSDR 1999b). Excretion of methylmercury and other organic forms of mercury is thought to occur predominately in the feces through biliary excretion. Studies with animals indicate that methylmercury, but not inorganic mercury, can be reabsorbed from the gall bladder and the intestine, resulting in a biliary-hepatic cycle that contributes to longer clearance half-times for methylmercury compared with inorganic mercury (ATSDR 1999b). Intestinal flora and various mammalian tissues can produce the divalent mercury ion from methylmercury presumably via hydroxyl radicals produced by cytochrome P450 reductase (ATSDR 1999b). Inorganic mercury enters an oxidation-reduction equilibrium between itself, mercurous mercury (Hg^+^), and metallic mercury (Hg^0^) (ATSDR 1999b).

## D.2 Health Effects

The nervous system is one of the primary sites of toxicity in humans and animals following exposure to elemental mercury, methylmercury, or inorganic salts of mercury (ATSDR 1999b). Neurological and behavioral disorders (including hand tremors, emotional lability, and performance deficits in tests of cognitive and motor function) have been observed in humans following inhalation of metallic mercury vapor, ingestion or dermal application of medicinal products containing inorganic mercurous salts, or ingestion of seafood contaminated with methylmercury. A single case study of lethal ingestion of mercuric chloride reported neurological symptoms and brain lesions. Animal studies have demonstrated changes in neurobehavioral function, morphology of neurological tissues, and brain neurochemistry following inhalation exposure to metallic mercury or oral exposure to methylmercury. Data for neurological effects of inorganic mercuric mercury salts are limited, and whether these effects were associated with oral dosing is uncertain. Effects on neurological development ranging from delays in motor and verbal development to severe brain damage have been observed in children of human mothers orally exposed to organic forms of mercury, including methylmercury (ATSDR 1999b). Animal studies provide confirmatory evidence that neurological development of the fetus can be impaired by exposure of the dams by inhalation to elemental mercury or orally to methylmercury (ASTDR 1999b). Effects on neurological development appear to occur at much lower doses of methylmercury than those producing other effects discussed below (ATSDR 1999b).

The kidney is another major site of mercury toxicity. Degeneration or necrosis of the proximal convoluted tubules has been observed in humans and animals exposed to elemental mercury, inorganic mercury, or methylmercury (ATSDR 1999b). In the absence of renal tubular degeneration, exposure to inorganic mercury has been associated in several human cases and certain genetically disposed animals (New Zealand rabbits and certain strains of mice) with a toxic glomerular response (proteinuria, deposition of immune material in the renal mesangium and glomerular blood vessels, and minimal glomerular cell hyperplasia) that is thought to involve mercury-induced autoimmunity through a stimulation of the humoral and cellular immune systems and systemic autoimmunity (ATSDR 1999b; Hultman and Enestrom 1992; Hultman et al. 1994). Studies demonstrating an association of this type of autoimmune response with exposure to methylmercury were not located (ATSDR 1999b).

Immunosuppressive effects have also been associated with mercury exposure including decreased T-cell reactivity and decreased B cell levels in peripheral blood of mercury-exposed humans, increased susceptibility of mercury-exposed animals to infectious agents, and decreased natural killer cell activity in the spleen and blood of methylmercury-exposed rats (ATSDR 1999b; Hultman and Enestrom 1992; Ilback 1991; Ilback et al. 1991).

Effects on male and female reproductive organs or functions associated with mercury exposure include decreased sperm motility in male monkeys orally exposed to methylmercury, decreased spermatogenesis and degeneration of seminiferous tubules in male mice after prolonged oral exposure to methylmercury, impaired spermatogenesis and infertility in male rats and mice following parenteral administration of methylmercury, and increased abortions, increased resorptions, or decreased implantations in female monkeys, guinea pigs, and mice orally exposed to methylmercury (ATSDR 1999b).

## D.3 Mechanisms of Action

The high-affinity binding activity of divalent mercuric ion to thiol compounds or sulfhydryl groups of proteins is thought to be a central molecular mode involved in the various toxic actions of inorganic mercury and methylmercury (see ATSDR 1999b for review). The greater potency of methylmercury in producing toxic effects, relative to mercuric salts, is thought to be due to differences in dispositional processes, including gastrointestinal absorption and hepato-biliary recycling, leading to longer retention times and higher doses of the mercuric ion at sites of toxicity.

Mercury-induced damage to neurological or renal tissues has been postulated to involve oxidative stress damage from mercury-induced depletion of reduced glutathione levels, depolarization of mitochondrial inner membranes leading to hydrogen peroxide formation, and depleted levels of reduced pyridine nucleotides (ATSDR 1999b). It has been further postulated that neurons are particularly sensitive to mercury because of their low endogenous glutathione content or their inefficient glutathione reduction activity (ATSDR 1999b).

Postulates regarding methylmercury’s mechanism of action on the developing nervous system include inhibitory effects of methylmercury on mitosis through impairment of microtubule assembly, methylmercury and inorganic mercury inhibition of enzymes such as protein kinase C, and inhibition of transport mechanisms in developing brain cells (ATSDR 1999b).

Molecular and cellular events underlying the immunosuppressive effects of mercury such as increased susceptibility to infectious agents are unclear, but Shenker et al. (1993) showed that methylmercury or mercuric chloride inhibited the mitogenic responses of cultured human T or B cells at concentrations that were about 10-fold lower than those that caused cytotoxicity, and that methylmercury was more potent than mercuric chloride. These authors postulated that immunosuppression involves inhibition by mercury of early stages in the response of these cells to mitogens. The genetically-controlled autoimmunity response to mercury that leads to glomerulonephropathy has been proposed to involve mercury disruption of the balance of helper and suppressor cells within the immunoregulatory network, but the molecular and cellular events that lead to glomerular immune-complex deposits have not been elucidated (ATSDR 1999b). Hultman et al. (1994) showed that, in a genetically susceptible mouse strain, prolonged exposure to inorganic mercury caused glomerular immune-complex deposits as well as stimulation of humoral immunity (increased levels of IgM and IgG1), cellular immunity (increased expression of class II molecules and increased mitogen-induced proliferation of T and B cells), and systemic autoimmunity (increased autoantibodies against the necleolus).

## D.4 Health Guidelines

ATSDR (1999b) derived a chronic oral MRL of 0.0003 mg Hg/kg/day for methylmercury based on observations of no adverse effects in a 66-month evaluation of neurobehavioral development in children who were conceived, born, and resided on the Seychelles Islands and were members of an isolated population that consumed a high quantity and variety of ocean fish containing methylmercury. A NOAEL of 0.0013 mg methylmercury/kg/day was calculated based on an average level of mercury in maternal hair, 15.3 ppm, from a group (n=95) of the most highly exposed mothers. The NOAEL was divided by a factor of 4.5 to arrive at the MRL. The factor of 4.5 was the sum of an uncertainty factor of 3 (1.5 to address variability in hair-to-blood ratios among women and fetuses in the U.S. population plus 1.5 to address any additional sources of human variability in response to methylmercury) and a modifying factor of 1.5 to address uncertainty regarding the sensitivity of the neurobehavioral tests used in the available report of the Seychelles Islands cohort study.

ATSDR (1999b) did not derive acute or intermediate-duration oral MRLs or any inhalation MRLs for methylmercury due to the absence of data or the lack of sufficient information regarding exposure levels associated with observed effects. ATSDR (1999b) derived acute and intermediate duration oral MRLs for inorganic mercury based on NOAELs for renal effects in rats exposed to mercuric chloride, but did not derive a chronic oral MRL for inorganic mercury due to inadequate data.

EPA (IRIS 2001e) derived a chronic oral RfD of 0.0001 mg/kg/day for methylmercury based on an estimated NOAEL of 1.1 µg/kg/day for delayed onset of walking and talking, low clinical neurological scores (<3), mental symptoms, or seizures in infants born to Iraqi mothers who ate contaminated bread during pregnancy. The NOAEL was estimated by a benchmark dose approach as the 95% lower confidence limit for a daily dietary intake associated with 10% incidence for the above neurological effects. The NOAEL was divided by an uncertainty factor of 10 to derive the RfD (3 for human variability including variability in biological half-life of methylmercury and hair:blood ratios and 3 for database deficiencies including the lack of a two-generation reproductive study and lack of data on the effect of exposure duration on developmental neurological effects and adult paresthesia).

EPA (IRIS 2001e) classified methylmercury in Group C—possible human carcinogen, based on inadequate data in humans and limited evidence of carcinogenicity in animals. The animal evidence was judged to be limited because: methylmercury-induced tumors (kidney tumors) were observed at a single site, in a single species and in a single sex; the tumors were observed only in the presence of profound nephrotoxicity; several nonpositive cancer bioassays have also been reported; and the evidence that methylmercury is genotoxic is equivocal. Quantitative estimates of cancer risk from oral or inhalation exposure were not derived based on evidence that methylmercury exerts its carcinogenic effects only at high doses above a maximum tolerated dose and that systemic noncancer effects on the nervous system would be seen at methylmercury exposure levels lower that those required to produce kidney damage and subsequent kidney tumor development.

## D.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for oral exposure to methylmercury were derived for endpoints affected by methylmercury and one or more of the other chemicals in the CDD-hexachlorobenzene-DDE-methylmercury mixture that is the subject of this Interaction Profile, using the methods described in ATSDR (1999a, Section 2.3.2). The relevant endpoints for methylmercury in this mixture include immunological, neurological, reproductive, and developmental effects. Chronic oral TTDs for these endpoints are derived below. The derivations are based on data provided in ATSDR (1999b), and in particular, the oral LSE table. Where the data were inadequate to derive a chronic oral TTD for a given endpoint, the chronic oral MRL is recommended as a conservative alternative that is protective of human health.

### Immunological Effects

Although immunosuppression is a known toxic endpoint for mercury, quantitative dose-response information for methylmercury is limited. Ilback (1991) reported a LOAEL of 0.5 mg Hg/kg/day for decreased thymus weight and cell number and reduced natural killer cell activity in mice fed methylmercury in the diet for 12 weeks. No other data were located regarding oral exposure to organic mercury (ATSDR 1999b). Because a free standing intermediate LOAEL with no supporting data is not a suitable basis for TTD derivation, the chronic oral MRL of 0.0003 mg Hg/kg/day is adopted as TTD_IMMUNO_ for methylmercury. Using the chronic oral MRL as the TTD is protective of human health.

### Neurological Effects

The neurological effects of methylmercury are well known in humans and animals (ATSDR 1999b). Effect levels in humans have not been identified, but animal studies have reported degenerative lesions in the central nervous system and functional deficits at doses as low as 0.015 mg Hg/kg/day with intermediate and chronic exposure. As described in Section D.4 above, the chronic oral MRL developed by ATSDR (1999b) is based on a NOAEL for neurological effects in a sensitive population (developing children). Therefore, the chronic oral MRL should be protective for neurological effects in other individuals as well.

### Reproductive Effects

Studies of the reproductive effects of methylmercury are described in ATSDR (1999b). The lowest reliable LOAEL for reproductive effects was 0.06 mg Hg/kg/day, which produced an increased rate of reproductive failure due to decreased conceptions and increased early abortions and stillbirths in female monkeys treated with methylmercury for 4 months (Burbacher et al. 1988). The NOAEL in this study was 0.04 mg Hg/kg/day. Although there was a report of sperm effects in male monkeys exposed to 0.025 or 0.035 mg Hg/kg/day by gavage for 20 weeks (Mohamed et al. 1987), this study was not considered reliable by ATSDR (1999b). Chronic studies in rodents reported testicular lesions (tubular atrophy) and decreased spermatogenesis at approximately 0.7 mg Hg/kg/day, with NOAEL values of roughly 0.1 mg Hg/kg/day in both sexes (Hirano et al. 1986; Mitsumori et al. 1990; Verschuuren et al. 1976). The 4-month monkey study is a suitable basis for a TTD. Application of an uncertainty factor of 100 (10 for extrapolation from monkeys to humans and 10 to protect sensitive individuals) to the NOAEL of 0.04 mg Hg/kg/day yields a TTD_REPRO_ of 0.0004 mg Hg/kg/day, which is only slightly higher than the chronic oral MRL of 0.0003 mg Hg/kg/day.

### Developmental Effects

As described in Section D.4 above, the chronic oral MRL for methylmercury (ATSDR 1999b) is based on a NOAEL for developmental effects (neurobehavioral development) in children. Therefore, the chronic oral MRL of 0.0003 mg Hg/kg/day is suitable for use to assess the developmental effects of methylmercury exposure.

### Summary (TTDs for methylmercury)

TTD_IMMUNO_ = 0.0003 mg Hg/kg/day (3×10^−4^mg/kg/day)

MRL_(NEURODEVELOP)_ = 0.0003 mg Hg/kg/day (3×10^−4^ mg/kg/day; chronic MRL)

TTD_REPRO_ = 0.0004 mg Hg/kg/day (4×10^−4^ mg/kg/day)