# 5. References

ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1995. Toxicological profile for diethyl phthalate. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1997. Toxicological profile for di-n-octyl phthalate. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins: December 1998. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2001a. Toxicological profile for di-n-butyl phthalate. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2001b. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2002. Toxicological profile for di(2-ethylhexyl)phthalate. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2004a. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2004b. Interaction profile for benzene, toluene, ethylbenzene, and xylenes (BTEX). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2004d. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2012. Addendum to the 1998 Toxicological profile for chlorinated dibenzo-p-dioxins. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
ATSDR. 2017. Toxicological profile for polybrominated biphenyls and polybrominated diphenyl ethers (update). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Aylward LL, Hays SM. 2002. Temporal trends in human TCDD body burden: decreases over three decades and implications for exposure levels. J Expo Anal Environ Epidemiol 12:319–328.12198580
Brown DJ, Van Overneire I, Goeyens L, 2004. Analysis of Ah receptor pathway activation by brominated flame retardants. Chemosphere 55(2004):1509–1518.15099731
CDC. 2006. National Health and Nutrition Examination Survey. Atlanta, GA: CDC/NCEH. Department of Health and Human Services, Centers for Disease Control and Prevention.
Chen G and Bunce NJ. 2003. Polybrominated diphenyl ethers as Ah receptor agonists and antagonists. Toxicol Sci 76:310–320.14514964
Huang PC, Kuo PL, Guo YL, 2007. Association between urinary phthalate monesters and thyroid hormones in pregnant women. Hum Reprod 22(10):2715–2722.17704099
Koch HM, Presuss R, Angerer J. 2006. Di(2-ethylhexyl)phthalate (DEHP): Human metabolism and internal exposure-- an update and latest results. Int J Androl (1):155–165; discussion 181–185.16466535
Meeker JD, Calafat AM, Hauser R. 2007. Di(2-ethylhexyl) phthalate metabolites may alter thyroid hormone levels in men. Environ Health Perspect 115(7):1029–1034.17637918
Peters AK, van Londen K, Bergman A, 2004. Effects of polybrominated diphenyl ethers on basal and TCDD-induced Ethoxyresorufin activity and cytochrome P450–1A1 expression in MCF-7, HepG2, and H4IIE cells. Toxicol Sci 82:488–496.15456928
Peters AK, Sanderson JT, Bergman A, 2006a. Antagonism of TCDD-induced Ethoxyresorufin-O-deethylation activity by polybrominated diphenyl ethers (PBDEs) in primary cynomolgus monkey (Macaca fascicularis) hepatocytes. Toxicol Lett 164(2006):123–132.16448790
Peters AK, Nijmeijer S, Gradin K, 2006b. Interactions of polybrominated diphenyl ethers with the aryl hydrocarbon receptor pathway. Toxicol Sci 92(1):133–142.16601081
Pohl HR. 2009. Chemical mixtures: Validation of weight-of-evidence predictions for interactions. The 29th International Symposium on Halogenated Persistent Organic Pollutants. August 23–28, 2009, Beijing, China.
Rider CV, Furr JR, Wilson VS 2010. Cumulative effects of in utero administration of mixtures of reproductive toxicants that disrupt common target tissues via diverse mechanisms of toxicity. Int J Androl 33:443–462.20487044
Sanders JM, Burka LT, Smith CS, 2005. Differential expression of CYP1A1, 2B, and 3A genes in the F344 rat following exposure to a polybrominated diphenyl ether mixture or individual components. Toxicol Sci 88(1):127–133.16107549
Schecter A, Papke O, Chi Tung K, 2005. Polybrominated diphenyl ether flame retardants in the U.S. population: current levels, temporal trends, and comparison with dioxins, dibenzofurans, and polychlorinated biphenyls. J Occup Environ Med 47(3):199–211.15761315
Tanida T, Warita K, Ishihara K, 2009. Fetal and neonatal exposure to three typical environmental chemicals with different mechanisms of action: Mixed exposure to phenol, phthalate, and dioxin cancels the effects of sole exposure on mouse midbrain dopaminergic nuclei. Toxicol Lett 189:40–47.19481886
Tomaszewski KA., Montgomery CA, Melnick RL. 1988. Modulation of 2,3,7,8-Tetrachlorobenzo-p-dioxin toxicity in F344 rats by di(2-ethylhexyl)phthalate. Chem Biol Int 65(1988):205–222.
Van den Berg M, Birnbaum L, Denison M, 2006. The 2005 World Health Organization reevaluation of human and mammalian toxic equivalency factors for dioxins and dioxin-like compounds. Toxicol Sci 93(2):223–241.16829543