# SUMMARY

The purpose of this profile is to investigate the possible joint actions of chlorinated dibenzo-p-dioxins (CDDs), polybrominated diphenyl ethers (PBDEs), and phthalates (also known as phthalate esters) on endocrine, developmental, and neurobehavioral endpoints in humans. Chemicals from all three of these classes are found in human blood, adipose tissue, and breast milk. In assessing the available information on possible interactions between these chemicals, this profile concludes with recommendations for conducting screening-level assessments of public health concerns from join exposures to mixtures of these chemical classes.

CDDs, PBDEs, and phthalates are ubiquitous in the environment. CDDs originate through incomplete combustion processes such as incineration. PBDEs had previous wide use as flame retardants in plastics and textiles. Phthalates are commonly used to make plastics soft and pliable. Oral exposure through food is believed to be the predominant mode of human exposure to these chemicals. CDDs and PBDEs are bio-persistent by virtue of their slow degradation and elimination from the body. Of the PBDEs, the lower brominated forms (primarily tetra- and pentabrominated diphenyl ethers [BDEs]) are the primary forms found in human tissues and fluids. Deca-brominated BDEs (decaBDE) are not readily absorbed into the body. Phthalates are rapidly m etabolized and eliminated from the body, but as exposure to phthalates is considered continuous, phthalates and their metabolites are continuously cycling through the body.

Observations in humans and laboratory animals following exposure to each of these chemicals alone raise concern about the nature and magnitude of possible effects associated with concurrent exposure. Exposure to chemicals in each of these classes alone has been associated with disruption of thyroid function in humans and/or animals, and with adverse effects on fetal development, especially fetal endocrine disruption in animals. Animal studies indicate that 2,3,7,8-tetrachloro dibenzo-p-dioxin (TCDD) and lower-brominated PBDEs each disrupt neurobehavioral development, and that 2,3,7,8-TCDD, di-(2-ethylhexyl)phthalate (DEHP), and di-n-butyl phthalate (DBP) each disrupt male reproductive structure and function. Animals studies also demonstrate that 2,3,7,8-TCDD and phthalates (DEHP and DBP) disrupt both male and female reproductive development. Both TCDD and lower-brominated PBDEs each disrupt thyroid function in gestationally exposed animals.

Of the CDDs, 2,3,7,8-TCDD is widely believed to be the most toxic, and is considered representative of the class. There is a large body of evidence that supports a pivotal role for the aryl hydrocarbon receptor (AhR) in the mechanism of TCDD-induced toxicity. Due to structural similarities to 2,3,7,8-TCDD, PBDEs have been investigated for dioxin-like activity; however, a group of expert scientists assembled under the aegis of the World Health Organization (WHO) in 2005 concluded that PBDEs do not meet commonly a ccepted criteria to be considered “dioxin-like” with regard to their toxicity. Recent in vitro investigations from a variety of mammalian cell lines have demonstrated that PBDEs have negligible ability to bind to the AhR and are incapable of activating it to induce the cascade of events (the AhR signal transduction pathway) leading to induction of enzymes that are the hallmark of dioxin-like activity. However, companion in vitro studies designed to investigate the joint action of PBDEs and 2,3,7,8-TCDD on various stages of the AhR signal transduction pathway indicate that the lower PBDE congeners (such as those found in human blood, adipose tissue, and breast milk) antagonize TCDD-induced activation of the AhR signal transduction pathway, but the molecular nature of this antagonism is currently unclear. Given that these observations were made on isolated cells and at concentrations orders of magnitude higher than concentrations of PBDEs found in human body fluids, the environmental relevance of this apparent antagonism is uncertain. There is no evidence to suggest that phthalates interact with the AhR or express dioxin-like toxicity. In fact, the fetal and developmental toxicity of DEHP is likely mediated through the peroxisome proliferator-activated receptor (PPAR).

There are no studies in the literature that address the possible effects of concurrent whole-body exposure of humans or animals to a mixture of CDDs, PBDEs, and phthalates. The available mechanistic understanding of toxicity caused by each class of chemicals alone is not sufficient to reliably predict the direction or magnitude of any interaction between all three chemicals or between any two pairs of chemicals, except for PBDEs and TCDD. Whereas in vitro mechanistic evidence indicates that PBDEs antagonize TCDD activation of the AhR signal transduction pathway, there are no studies that address possible joint action of PBDEs and TCDD on any toxicity endpoint. Furthermore, the mechanistic evidence suggesting possible antagonism is offset by thyroid toxicity data for TCDD alone and PBDEs alone that suggest the possibility of joint additivity on the basis of a common non-AhR-mediated mode of action (i.e., inhibition of thyroxine [T_4_] binding by hydroxylated intermediates). There are no physiologically based toxicokinetic (PBTK) models that can be used to predict interactions between any pairs or sets of three chemicals from these three chemical classes.

Given the co-occurrence of CDDs, PBDEs, and phthalates in humans and the commonality of certain classes of effects, ATSDR recommends that the default assumption of joint additivity be employed to assess mixtures of these chemicals using a modified hazard index (HI) approach. To facilitate the use of this approach, target toxicity doses (TTDs) have been derived for thyroid disruption in adults, developmental endocrine disruption (either thyroid or reproductive hormone disruption), and neurodevelopmental toxicity for 2,3,7,8-TCDD, lower-brominated PBDEs, decaBDE, DEHP, di-n-octyl phthalate (DNOP), and DBP, where toxicity data were indicative of the effect of concern and were suitable for quantification of effect levels. No TTDs were derived for diethyl phthalate (DEP) or decaBDE due to the lack of effects of concern.

Exposure to CDDs should be determined as the sum of all congeners converted by toxic equivalence to TCDD. Exposure to PBDEs should be evaluated separately for the sum of the lower-brominated congeners and decaBDE mixtures. Exposure to DEHP, DNOP, and DBP should each be determined. The HI for each relevant endpoint (endocrine, neurobehavioral, and developmental) can be derived by summing the ratio of exposure to TTD for each chemical in the mixture that is associated with the effect of concern. HIs in excess of 1 indicate the potential for the mixture to be of greater concern than any individual component, usually resulting in the need for further study or limiting exposure through remedial action or education of the community regarding related issues.