# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Dale B. Hattis, PhD, Research Professor, George Perkins Marsh Institute, Clark University, Worcester, MA 01610–1477
- Raymond S. H. Yang, Ph.D., Professor Emeritus, Center for Environmental Toxicology and Technology, Colorado State University, Fort Collins, CO 80523–1680
- Harihara M. Mehendale, Ph.D., Professor of Toxicology, Kitty DeGree Endowed Chair, Department of Toxicology, College of Pharmacy, University of Louisiana at Monroe, Monroe, LA 71209–0497

All reviewers were selected in conformity with the conditions for peer review specified in CERCLA Section 104(I)(13).

Scientists from ATSDR have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this interaction profile. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.