# Appendix C Background Information for Phthalates

## Appendix C-1: Background Information for DEHP

DEHP is a synthetic chemical used as a plasticizer. DEHP is present in plastic products such as wall coverings, tablecloths, floor tiles, furniture upholstery, shower curtains, garden hoses, swimming pool liners, rainwear, baby pants, dolls, some toys, shoes, automobile upholstery and tops, packaging film and sheets, sheathing for wire and cable, medical tubing, and blood storage bags. In plastics, DEHP is physically mixed into the product, rather than chemically bound. Therefore, it has the potential to migrate from the plastic matrix into the surrounding media when conditions are appropriate (ATSDR 2002).

### C-1.1 Toxicokinetics

Human data indicate that gastrointestinal absorption of DEHP and its metabolites might amount to approximately 20–25% of an orally-administered dose (ATSDR 2002). Trace amounts of DEHP might be absorbed through the skin. No human data were available regarding the toxicokinetics of inhaled DEHP, although some degree of absorption from respiratory tissues would be expected. Animal data generally support the human findings. DEHP is hydrolyzed in the small intestine and absorbed as MEHP and 2-ethylhexanol. At high concentrations, a limited amount of unchanged DEHP might be absorbed. The degree of gastrointestinal absorption varies among animal species and is apparently greater in rodents than in monkeys. Animal studies indicate that DEHP might be absorbed through the skin in minute quantities. Absorption via the respiratory tract has also been indicated, although quantitative absorption studies have not been published.

Limited human data from autopsies have indicated the presence of DEHP in adipose tissues and kidneys. Studies in animals have shown the liver, kidneys, and testes to be major distribution sites for DEHP metabolism or utilization. Metabolic pathways for DEHP involve a number of reactions. Hydrolytic cleavage of DEHP results in the formation of MEHP and 2-ethylhexanol. The esterases responsible for these hydrolytic steps are found in numerous body tissues, but highest levels occur in the pancreas (hydrolytic reactions occur more readily following oral exposure because of the high content of esteratic activity within the gastrointestinal tract). MEHP is further metabolized via numerous oxidative reactions, resulting in the formation of 30 or more metabolites, some of which can be conjugated with glucuronic acid for excretion. Oxidation of 2-ethylhexanol primarily yields 2-ethylhexanoic acid and several keto acid derivatives, which are excreted in the urine.

In orally-exposed humans, approximately 65% of DEHP metabolites are excreted in the urine as glucuronide conjugates. The aglycone moiety of these conjugates as well as the nonconjugated DEHP metabolites excreted by humans are similar to those found in urine and feces of laboratory animals, although relative proportions might differ with species, dose, and time. No studies were located regarding fecal excretion of DEHP metabolites in humans. However, significant amounts of DEHP were noted in the feces of animals given DEHP by the oral route; this presumably represents unmetabolized DEHP. MEHP and other metabolites were frequently found in feces of DEHP-exposed animals, in some cases associated with biliary excretion products.

Because of their lipophilic nature, both DEHP and MEHP can accumulate in breast milk and subsequently be transferred to suckling offspring. This has been directly demonstrated in animals. DEHP has been detected in human breast milk.

### C-1.2 Health Effects

Limited information was located regarding effects of DEHP on the relevant endpoints evaluated in humans for this Interaction Profile mixture of chemicals. Rais-Bahrami et al. (2004) assessed the onset of puberty and sexual maturity in male and female adolescents who had been exposed to DEHP as neonates through extracorporeal membrane oxygenation. Other endpoints assessed included thyroid function as well as measurements of sex hormones. The results showed no significant adverse effects on physical growth and pubertal maturity; thyroid, liver, renal, and male and female gonadal functions were within normal range for age and sex distribution; exposure data were not available. A more recent study found that serum levels of DEHP were significantly higher in precocious girls compared with normal children and that DEHP in serum of precocious girls was positively correlated with the volume of the uterus and ovaries (Qiao et al. 2007). Information on thyroid function is also available in a recent small study of adult males in the United States that reported an inverse association between MEHP urinary concentration and free T_4_ and T_3_ levels (Meeker et al. (2007). Reduced follicle size and colloid density in the thyroid were reported in male and female rats dosed with 375 and 419 mg/kg/day DEHP, respectively, via the diet for 13 weeks (Poon et al. 1997), but no histopathological changes were observed in the thyroid from rats and mice treated with much higher doses for 2 years (David et al. 2000a, 2000b). Studies in animals, mostly rodents, have shown that DEHP induces abnormal development of the male reproductive tract following perinatal exposure (ATSDR 2002). A variety of effects have been observed in androgen-sensitive tissues of young male rats, including reduced (female-like) AGD and permanent nipples, vaginal pouch, penile morphological abnormalities, hemorrhagic and undescended testes, testicular and epididymal atrophy or agenesis, and small to absent sex accessory glands. In general, these effects were reported after perinatal exposure to ≥300 mg/kg/day (ATSDR 2002). These morphological effects, as well as reduced fetal and neonatal testosterone levels and adult sexual behavioral changes in male rats following gestational and lactational exposure, are consistent with an antiandrogenic action of DEHP. A more recent study (Borch et al. 2006) reported that administration of 300 mg/kg/day DEHP to pregnant rats resulted in reduced steroidogenesis in fetal testes leading to low fetal testosterone levels. This was accompanied by alteration in the expression of a number of testicular mRNA steroidogenesis factors. Both function and development of the reproductive system were adversely affected in male offspring of rats that were orally exposed to DEHP in a two-generation study. The changes in the development, structure, and function of the male reproductive tract observed in various studies indicate that effects of DEHP on reproduction and development are interrelated. Perinatal exposure (GD 7 to PD 16) of Wistar rats to 10 mg/kg/day of DEHP by gavage caused decreased AGD, increased incidence of nipple retention, reduced prostate weight, and mild dysgenesis of external genitalia in pups (Christiansen et al. 2010). Effects on female reproductive development have also been reported in recent studies. For example, Grande et al. (2006) reported that exposure of rats throughout gestation and lactation induced an earlier start of first estrus in female offspring; these effects occurred at doses ≥15 mg/kg/day, but not at 5 mg/kg/day. In another recent study, exposure of prepubertal female rats to DEHP by inhalation caused earlier onset of vaginal opening and first estrus cycle (Ma et al. 2006). Developmental toxicity studies also have shown that gestational exposure to DEHP can be embryotoxic and teratogenic in rats and mice. A range of effects have been observed including intrauterine deaths, skeletal and cardiovascular malformations, neural tube closure defects, increased perinatal mortality, and developmental delays. No information was located regarding neurobehavioral effects of DEHP.

### C-1.3 Mechanisms of Action

Male Reproductive System Development. Considerable research has been conducted to elucidate the mechanism(s) by which exposure to DEHP during gestation and lactation alters the development of the reproductive system in male rat offspring. The reported effects observed in androgen-sensitive tissues of male neonates and infants, including female-like AGD and permanent nipples, vaginal pouch, penile morphological abnormalities, hemorrhagic and undescended testes, testicular and epididymal atrophy or agenesis, and small to absent sex accessory glands (Gray et al. 1999, 2000; Moore et al. 2001; Parks et al. 2000) are consistent with an antiandrogenic action of DEHP. Consistent with this view are the results of a study in which exposure to DEHP from GD 14 to PND 3 caused significantly reduced testicular testosterone production and reduced testicular and whole-body testosterone levels in fetal and neonatal male rats (Parks et al. 2000). Histological examinations of the testes in these rats showed that DEHP induced increased numbers of multifocal areas of Leydig cell hyperplasia, as well as multinucleated gonocytes, at GD 20 and PND 3. However, in vitro assays have shown that neither DEHP nor its metabolite MEHP displayed significant affinity for the human androgen receptor (Paganetto et al. 2000; Parks et al. 2000). The available evidence indicates that DEHP is not an androgen receptor antagonist, but acts as an antiandrogen during a critical stage of reproductive tract differentiation by reducing testosterone to female levels in the fetal male rat. Parks et al. (2000) hypothesized that DEHP, or a metabolite, reduces testosterone production either by directly acting on the Leydig cells to reduce testosterone synthesis, or by interfering with Sertoli cell paracrine factors that regulate Leydig cell differentiation and function. Regardless of the mechanism, if the Leydig cells in exposed males continue to divide rather than differentiate for only a brief period of sexual differentiation, this could delay the onset of Leydig cell testosterone production and lead to malformations of the reproductive tract, external genitalia, and other androgen-dependent tissues (e.g., nipples) (Parks et al. 2000). Recent studies have suggested that alterations in testicular testosterone production are, in turn, due to alterations in the expression of a number of mRNA steroidogenesis-related factors (Borch et al. 2006). In general, results from in vivo and in vitro studies indicate that DEHP has negligible estrogenic potency relative to the endogenous hormone, 17β-estradiol.

Fetotoxicity/Teratogenicity. The mechanism(s) of fetotoxicity/teratogenicity of DEHP has not been elucidated, but there are studies that sought to determine whether these effects are mediated by PPAR-alpha (PPARα). Peters et al. (1997) assessed pregnancy outcome in female F_4_C57BL/6N × Sv/129, wild type (+/+), and PPARα-null (−/−) mice on GDs 10 and 18 after administration of DEHP by gavage on GDs 8 and 9. PPARα-null mice lack expression of PPARα protein and are refractive to peroxisomal proliferators (Lee et al. 1995). Relative to controls, DEHP significantly decreased the percentage of live fetuses, increased the percentage of resorptions, decreased fetal weight, and increased the percentage of fetuses with external malformations in both mice strains. On GD 10, maternal liver CYP4A1 mRNA was significantly elevated in DEHP-treated (+/+) mice but not in (−/−) mice, consistent with their respective phenotype. Mean maternal liver metallothionein and zinc levels were significantly higher in DEHP-treated mice (both strains) compared to controls. Maternal plasma zinc was not significantly altered as a result of treatment with DEHP. Embryonic zinc was significantly reduced in conceptus from both mice strains. These findings indicated that DEHP-induced fetotoxicity and teratogenicity, and altered zinc metabolism are not mediated through PPARα-dependent mechanisms, and that alterations in zinc metabolism might contribute to the mechanism underlying DEHP-induced fetotoxicity and teratogenicity.

### C-1.4 Health Guidelines

ATSDR (2002) derived an MRL of 0.1 mg/kg/day for intermediate-duration oral exposure to DEHP based on a NOAEL of 14 mg/kg/day for decreased fertility in mice. This derivation used an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

ATSDR (2002) derived an MRL of 0.06 mg/kg/day was derived for chronic-duration oral exposure to DEHP based on a NOAEL of 5.8 mg/kg/day for testicular pathology in male rats that were exposed to DEHP in the diet for up to 104 weeks in a chronic toxicity study. The chronic MRL was derived by dividing the 5.8 mg/kg/day NOAEL by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability).

EPA (IRIS 2007) derived a chronic oral RfD of 0.02 mg/kg/day for DEHP based on a LOAEL of 19 mg/kg/day for hepatic effects in guinea pigs fed a diet containing DEHP for 1 year. The RfD was derived by applying an uncertainty factor of 1,000 (10 for interspecies and 10 for intraspecies extrapolation and 10 for using a LOAEL) to the LOAEL.

NTP (2004) determined that DEHP may reasonably be anticipated to be a human carcinogen. IARC (2006) has classified DEHP in Group 3, cannot be classified as to its carcinogenicity to humans. The EPA (IRIS 2007) classified DEHP in Group B2, probable human carcinogen based on inadequate data in humans and sufficient evidence in animal studies. Based on updated guidelines for carcinogen risk assessment (EPA 2005), this compound is classified as a chemical that is likely to be carcinogenic to humans.

### C-1.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The endpoints of concern for DEHP in this Interaction Profile mixture of chemicals are endocrine, neurobehavioral, and developmental. TTDs are derived below for endpoints that are not the basis of the MRL, using the methods described by ATSDR (2004a). The derivations are based primarily on data provided in ATSDR (2002), and in particular the LSE tables.

#### Thyroid Effects (Adults)

Limited information is available in humans. Rais-Bahrami et al. (2004) reported no alterations in thyroid function in a group of male and female adolescents who had been exposed to DEHP as neonates through extracorporeal membrane oxygenation. A study of adult males from the U.S. population reported an inverse association between the concentration of MEHP in the urine and free T_4_ and T_3_ levels, although the relationship did not appear to be linear when MEHP concentrations were categorized by quintiles (Meeker et al. 2007). The lowest LOAEL for thyroid effects in animals is 375 mg/kg/day for reduced follicle size and mild reduction in colloid density in male rats in a 90-day study (Poon et al. 1997). A 2-year dietary study reported no gross or microscopic alterations in the thyroid from rats and mice that received doses of 939 and 1,458 mg/kg/day, respectively (David et al. 2000a, 2000b). Neither of these studies measured serum levels of thyroid hormones or TSH. Since no histological alterations were seen in the 2-year study, it would appear that the alterations seen in the 90-day study may have been transient and without long-lasting consequences for the animal. The NOAEL in the 90-day study was 38 mg/kg/day and can be used to derive a TTD_THYROID_. Applying an uncertainty factor of 100 (10 for animal-to-human extrapolation and 10 for human variability) to the NOAEL of 38 mg/kg/day results in a TTD_THYROID_ of 0.4 mg/kg/day for DEHP. An additional uncertainty factor to account for extrapolation from intermediate-duration to chronic-duration exposure is not necessary on the grounds that the effects observed after 90 days of exposure were not present after 2 years of exposure to significantly higher doses.

#### Developmental Endocrine Effects

The lowest LOAEL for developmental effects was identified in a recent study that evaluated reproductive development of female offspring from rats treated daily with doses of up to 405 mg/kg/day DEHP by gavage from GD 6 to lactation day 22 (Grande et al. 2006). A significant delay in the age at vaginal opening (approximately 2 days) was observed at ≥15 mg DEHP/kg/day, as well as a trend for a delay in the age at first estrus at ≥135 mg/kg/day (approximately 2 days); the NOAEL was 5 mg/kg/day. Applying an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) to the NOAEL of 5 mg/kg/day results in a TTD_DEVELOPMENTAL_ of 0.05 mg/kg/day for DEHP.

#### Neurobehavioral Effects

A TTD_NEUROBEHAVIORAL_ cannot be derived due to the lack of information on the potential neurobehavioral effects of DEHP.

#### Summary (TTDs for DEHP)

TTD_THYROID_ = 0.4 mg/kg/day

TTD_DEVELOPMENTAL_ = 0.05 mg/kg/day (based on reproductive endocrine effects)

TTD_NEUROBEHAVIORAL_ = not derived

### C-1.6 References

ATSDR. 2002. Toxicological profile for di(2-ethylhexyl)phthalate (update). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2004. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Borch J, Metzdorff SB, Vinggaard AM, 2006. Mechanisms underlying the anti-androgenic effects of diethylhexyl phthalate in fetal rat testis. Toxicology 223:144–155.16690193
Christiansen S, Boberg J, Axelstad M, 2010. Low-dose perinatal exposure to di(2-ethylhexyl) phthalate induces anti-androgenic effects in male rats. Reprod Toxicol 30(2):313–321.20420898
David RM, Moore MR, Finney DC, 2000a. Chronic toxicity of di(2-ethylhexyl)phthalate in rats. Toxicol Sci 55:433–443.10828276
David RM, Moore MR, Finney DC, 2000b. Chronic toxicity of di(2-ethylhexyl)phthalate in mice. Toxicol Sci 58:377–385.11099649
EPA. 2005. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
Grande SW, Anderson JM, Andrade CE, 2006. A dose-response study following in utero and lactational exposure to di(2-ethylhexyl)phthalate: Effects on female rat reproductive development. Toxicol Sci 91:247–254.16476687
Gray LE, Ostby J, Furr J, 2000. Perinatal exposure to the phthalates DEHP, BBP, and DINP, but not DEP, DMP, or DOTP, alters sexual differentiation of the male rat. Toxicol Sci 58:350–365.11099647
Gray LE, Wolf C, Lambright C, 1999. Administration of potentially antiandrogenic pesticides (procymidone, linuron, iprodione, chlozolinate, p,p'-DDE, and ketoconazole) and toxic substances (dibutyl- and diethylhexyl phthalate, PCB 169, and ethane dimethane sulphonate) during sexual differentiation produces diverse profiles of reproductive malformation in the male rat. Toxicol Ind Health 15:94–118.10188194
IARC. 2007. Agents reviewed by the IARC monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. December 14, 2007.
IRIS. 2007. Integrated Risk Information System. U.S. Environmental Protection Agency. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. December 14, 2007.
Lee SS T, Pineau T, Drago J, 1995. Targeted disruption of the alpha isoform of the peroxisome proliferator-activated receptor gene in mice results in abolishment of the pleiotropic effects of peroxisome proliferators. Mol Cell Biol 15(6):3012–3022.7539101
Ma M, Kondo T, Ban S, 2006. Exposure of prepubertal female rats to inhales di(2-ethylhexyl)phthalate affects the onset of puberty and postpubertal reproductive functions. Toxicol Sci 93:164–171.16763069
Meeker JD, Calafat AM, Hauser R. 2007. Di(2-ethylhexyl) phthalate metabolites may alter thyroid hormone levels in men. Environ Health Perspect 115:1029–1034.17637918
Moore RW, Rudy TA, Lin T- M, 2001. Abnormalities of sexual development in male rats with in utero and lactational exposure to the antiandrogenic plasticizer. Environ H ealth Perspect 109:229–237.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. December 14, 2007.
Parks LG, Ostiby JS, Lambright CR, 2000. The plasticizer diethylhexyl phthalate induces malformations by decreasing fetal testosterone synthesis during sexual differentiation in the male rat. Toxicol Sci 58:339–349.11099646
Paganetto G, Campi F, Varani K, 2000. Endocrine-disrupting agents on healthy human tissues. Pharmacol Toxicol 86:24–29.10720103
Peters JM, Taubeneck MW, Keen CL, 1997. Di(2-ethylhexyl)phthalate induces a functional zinc deficiency during pregnancy and teratogenesis that is independent of peroxisome proliferator-activated receptor-α. Teratology 56:311–316.9451755
Poon R, Lecavalier P, Mueller R, 1997. Subchronic oral toxicity of di-n-octyl phthalate and di(2-ethylhexyl) phthalate in the rat. Food Chem Toxicol 35:225–239.9146736
Qiao L, Zheng L, Cai D. 2007. Study on the di-n-butyl phthalate and di-2-ethylhexyl phthalate level of girl serum related with precocious puberty in Shanghai. Wei Sheng Yan Jiu 36:93–95. [Chinese]17424861
Rais-Bahrani K, Nuñez S, Revenis ME, 2004. Follow-up study of adolescents exposed to di(2-ethylhexyl) phthalate (DEHP) as neonates on extracorporeal membrane oxygenation (ECMO) support. Environ Health Perspect 112:1339–1340.15345350

## Appendix C-2: Background Information for DBP

DBP is a synthetic chemical used as a plasticizer. The plastics that DBP is used most in are polyvinyl chloride (PVC) plastics and nitrocellulose lacquers. These plastics are used to make products such as carpets, paints, glue, insect repellents, hair spray, nail polish, and rocket fuel. In plastics, DBP is physically mixed into the product, rather than chemically bound. Therefore, it has the potential to migrate from the plastic matrix into surrounding media under appropriate conditions (ATSDR 2001).

### C-2.1 Toxicokinetics

The only information regarding toxicokinetics of DBP in humans is from a study in which volunteers given an oral dose of 0.255–0.510 mg DBP subsequently excreted approximately 70% as MBP in the urine after 24 hours (NTP 2000). This suggests that DBP is absorbed and metabolized (or metabolized and absorbed) by humans. Data in animals suggest that airborne DBP may be rapidly absorbed through the lungs and that oral doses are rapidly and extensively absorbed (ATSDR 2001). A study in rats showed that approximately 60% of a single dermal dose was absorbed during a 7-day period. Animal data suggest that following inhalation, oral, or dermal exposure, DBP is widely distributed throughout the body and does not accumulate in the body. There are no data on transplacental transfer or transfer via maternal milk. There is some evidence to suggest that DBP and its metabolites are rapidly cleared from the body. Thus, it is unlikely that DBP will be stored in maternal tissues and released during pregnancy or lactation. In animals, the metabolism of DBP proceeds mainly by hydrolysis of one butyl ester bond to yield MBP. The product that appears in the urine is mainly MBP conjugated with glucuronic acid, with lower levels of unconjugated MBP, various oxidation products of MBP, and a small amount of the free phthalic acid. Studies in rats, hamsters, and guinea pigs indicate that excretion of a single oral dose is essentially complete by within 48 hours of dosing, mostly (63–97%) via the urine.

### C-2.2 Health Effects

Limited information is available for humans regarding effects of DBP on the relevant endpoints evaluated for the mixture of chemicals in this IP. A study reported that serum levels of DBP and DEHP were significantly higher in precocious girls compared with normal children and that DBP and DEHP in serum of precocious girls was positively correlated with the volume of the uterus and ovaries (Qiao et al. 2007). A recent systematic review and meta-analysis study reported that exposure of DEHP and DBP might be associated with precocious puberty risk for girls. The authors indicated that the association is of “moderate strength” (Wen et al. 2015). An additional study found negative associations between urinary levels of MBP, the main metabolite of DBP, and serum levels of thyroid hormones in pregnant women during the second trimester, after adjusting for age, body mass index, and gestation (Huang et al. 2007). In rats and mice, administration of up to 2,964 and 4,278 mg/kg/day DBP, respectively, in the diet for 13 weeks did not cause any significant gross or microscopic changes in the thyroid (NTP 1995). In another 90-day dietary study in rats, doses of 752 mg/kg/day DBP induced a significant decrease in total T_3_, but did not affect total T_4_ or the microscopic morphology of the thyroid gland; the NOAEL was 152 mg/kg/day (Schilling et al. 1992). Animal studies have also shown that acute- and intermediate-duration oral exposure to DBP causes a number of developmental effects, including increases in postimplantation losses, decreases in the number of live fetuses per litter, decreases in fetal/pup body weights, and increases in incidences of external, skeletal, and internal malformations (ATSDR 2001). The lowest levels at which these effects were seen varied widely. Decreases in the number of live pups/litter were seen following doses of 80 mg/kg/day in rats and 1,950 mg/kg/day in mice. Perinatal administration of DBP causes alterations in the development of the reproductive system of rodents (ATSDR 2001). Recent studies indicate that these effects can occur at relatively low levels of exposure. For example, administration of ≥2.5 mg/kg/day DBP during gestation and lactation reduced testicular spermatocyte development and mammary gland changes in male and female offspring on PND 21 (Lee et al. 2004). In another study, perinatal administration of 12 mg/kg/day DBP to rats induced a significant delay in vaginal opening in female pups (Salazar et al. 2004). In yet another study, doses of 50 mg/kg/day DBP, but not 10 mg/kg/day, administered to rats on GDs 12–19 significantly reduced fetal testicular testosterone (Lehmann et al. 2004). Higher doses, in the range 100–500 mg/kg/day, administered perinatally, induced a variety of effects in male offspring including decreased AGD, retention of areolas or nipples, small sex accessory glands, and reduced testes weight, and produced malformations of the reproductive tract (ATSDR 2001). Similarly, when the impact of DBP exposure during the masculinization programming window was tested in rats, DBP significantly decreased the penis size and the ventral prostate and seminal vesicles sizes, and reduced AGD (Macleod et al. 2010). No information was located regarding neurobehavioral effects of DBP.

### C-2.3 Mechanisms of Action

The specific mechanisms by DBP affect the development of the male reproductive system in animals have not been determined, but since the effects are similar to those induced by DEHP, the mechanisms discussed for DEHP are applicable to DBP (see Appendix C-1).

The results from several studies suggest that DBP has anti-androgenic properties (i.e., Ema et al. 1998, 2000; Mylchreest et al. 1999, 2000). This is further supported by the findings of similar, but not identical, effects from DBP exposure as from exposure to linuron, a known androgen receptor ligand (Gray et al. 1999). These effects included delayed preputial separation, reduced fertility, testicular atrophy, and reduced sperm production in treated males, and reduced AGD, increased number of retained nipples, and decreased androgen-dependent tissue weights in male offspring (exposed in utero and via lactation only) of treated rats. However, these androgen-related effects do not appear to be mediated by interaction of DBP or its primary metabolite, MBP, with the androgen receptor (Mylchreest et al. 1998, 1999). Parks et al. (2000) hypothesized that the unchanged phthalate ester, or a metabolite, reduces testosterone production either by directly acting on the Leydig cells to reduce testosterone synthesis, or by interfering with Sertoli cell paracrine factors that regulate Leydig cell differentiation and function. Regardless of the mechanism, if the Leydig cells in exposed males continue to divide rather than differentiate for only a brief period of sexual differentiation, this could delay the onset of Leydig cell testosterone production and lead to malformations of the reproductive tract, external genitalia, and other androgen-dependent tissues (e.g., nipples) (Parks et al. 2000).

The results from in vitro and in vivo assays for estrogenicity have provided evidence of weak estrogenic activity for DBP. In one in vitro assay, DBP was approximately 10-million-fold less potent than 17β-estradiol (Harris et al. 1997). In another in vitro assay, DBP was approximately 3,000-fold less potent than 17β-estradiol (Zacharewski et al. 1998). The negative results obtained in vivo may be due, at least in part, to the presence in vivo of esterases that metabolize DBP to MBP, which has been reported not to interact with the estrogen receptor (Mylchreest et al. 1998).

### C-2.4 Health Guidelines

ATSDR 2001) derived an acute-duration oral MRL of 0.5 mg/kg/day for DBP based on a NOAEL of 50 mg/kg/day for developmental effects in the offspring of rats exposed to DBP on GDs 12–21. The MRL was derived by dividing the NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

EPA (IRIS 2007) derived an RfD of 0.1 mg/kg/day for DBP based on a NOAEL of 125 mg/kg/day for increased mortality in rats in a 1-year dietary study. An uncertainty factor of 1,000 was applied to the NOAEL (10 for animal to human extrapolation, 10 for human variability, and 10 for less than chronic duration study and study deficiencies).

NTP (2004) and IARC (2006) do not include DBP in their listings. The EPA (IRIS 2007) classified DBP in Group D, not classifiable as to human carcinogenicity, based on no human or animal data. Based on updated guidelines for carcinogen risk assessment (EPA 2005), this compound is classified as a chemical for which there in inadequate information to assess carcinogenic potential.

### C-2.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The endpoints of concern for DBP in the mixture of chemicals in this Interaction Profile are thyroid, neurobehavioral, and developmental. TTDs are derived below for endpoints that are not the basis of the MRL, using the methods described by ATSDR (2004a). The derivations are based primarily on data provided in ATSDR (2001), in particular the LSE tables, but more recent information regarding the endpoints of concern in this mixture that is likely to impact the existing MRLs has also been considered.

#### Thyroid Effects (Adults)

A recent epidemiological study reported negative associations between urinary levels of MBP, the main metabolite of DBP, and serum levels of thyroid hormones in pregnant women during the second trimester, after adjusting for age, body mass index, and gestation (Huang et al. 2007). Exposure doses, however, were not available; thus, this study cannot be used for derivation of a TTD_THYROID_. The lowest LOAEL from an animal study was 752 mg/kg/day for decreased total serum T_3_ in rats in a 90-day dietary study (Schilling et al. 1992). The NOAEL was 152 mg/kg/day and can be used to derive a TTD_THYROID_ of 1.5 mg/kg/day by dividing the NOAEL of 152 mg/kg/day by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability). An additional uncertainty factor to account for extrapolation from intermediate-duration to chronic-duration exposures does not appear necessary based on the results of 2-year studies in rats and mice exposed to significantly higher doses of the related DEHP (David et al. 2000a, 2000b). These studies, although they did not monitor serum hormone levels, did not find gross or microscopic alterations in the thyroid or clinical signs of hypo- or hyperthyroidism in the animals.

#### Developmental Endocrine Effects

The lowest developmental LOAEL is from a study by Lee et al. (2004) who administered DBP in the diet to pregnant rats from GD 15 to PND 21 and evaluated the development of the reproductive system of male and female pups until postnatal week 20. The dietary concentrations of DBP were 0, 20, 200, 2,000, and 10,000 ppm. Treatment with DBP caused vacuolar degeneration of the alveolar cells of the mammary gland in males evaluated on postnatal week 11. The severity of the lesion was dose-related. Higher doses also disrupted female sexual differentiation as evidenced by histopathological alterations in the prepubertal mammary gl and and changes in the pituitary weight and cell populations of pituitary hormones in the adult stage. According to the investigators, the changes in prepubertal and adult stage males suggested an organizational effect of DBP on the male endocrine system, possibly by affecting the hypothalamus-pituitary axis due to testosterone insufficiency. Since the lowest dietary concentration tested, 20 ppm (approximately 2.5 mg/kg/day, estimated by the investigators) caused changes of only minimal severity, it can be considered a minimal LOAEL. Applying an uncertainty factor of 300 (10 for animal to human extrapolation, 10 for human variability, and 3 for a minimal LOAEL) to the LOAEL of 2.5 mg/kg/day results in a TTD_DEVELOPMENTAL_ of 0.008 mg/kg/day.

#### Neurobehavioral Effects

A TTD_NEUROBEHAVIORAL_ cannot be derived due to the lack of information on the potential neurobehavioral effects of DBP.

#### Summary (TTDs for DBP)

TTD_THYROID_ = 1.5 mg/kg/day

TTD_DEVELOPMENTAL_ = 0.008 mg/kg/day (disruption of reproductive endocrine function)

TTD_NEUROBEHAVIORAL_ = not available

### C-2.6 References

ATSDR. 2001. Toxicological profile for di-n-butylphthalate (Update). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2004. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
David RM, Moore MR, Finney DC, 2000a. Chronic toxicity of di(2-ethylhexyl)phthalate in rats. Toxicol Sci 55:433–443.10828276
David RM, Moore MR, Finney DC, 2000b. Chronic toxicity of di(2-ethylhexyl)phthalate in mice. Toxicol Sci 58:377–385.11099649
Ema M, Miyawaki E, Kawashima K. 1998. Further evaluation of developmental toxicity of di-n-butyl phthalate following administration during late pregnancy in rats. Toxicol Lett 98:87–93.9776565
Ema M, Miyawaki E, Kawashima K. 2000. Effects of dibutyl phthalate on reproductive function in pregnant and pseudopregnant rats. Reprod Toxicol 14:13–19.10689199
EPA. 2005. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
Gray LE, Wolf C, Lambright C, 1999. Administration of potentially antiandrogenic pesticides (procymidone, linuron, iprodione, chlozolinate, p,p'-DDE, and ketoconazole) and toxic substances (dibutyl- and diethylhexyl phthalate, PCB 169, and ethane dimethane sulphonate) during sexual differentiation produces diverse profiles of reproductive malformations in the male rat. Toxicol Ind Health 15(1–2):94–118.10188194
Harris CA, Henttu P, Parker MG, 1997. The estrogenic activity of phthalate esters in vitro. Environ Health Perspect 105(8):802–811.9347895
Huang PC, Kuo PL, Gu YL, 2007. Associations between urinary phthalate monoesters and thyroid hormones in pregnant women. Human Rep 22:2715–2722.
IARC. 2006. Agents reviewed by the IARC monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. December 14, 2007.
IRIS. 2007. Integrated Risk Information System. U.S. Environmental Protection Agency. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. December 14, 2007.
Lee K-Y, Shibutani M, Tagaki H, 2004. Diverse developmental toxicity of di-n-butyl phthalate in both sexes of rat offspring after maternal exposure during the period from late gestation through lactation. Toxicology 203:221–238.15363597
Lehmann KP, Phillips S, Sar M, 2004. Dose-dependent alterations in gene expression and testosterone synthesis in the fetal testes of male rats exposed to di (n-butyl) phthalate. Toxicol Sci 81:60–68.15141095
Macleod DJ, Sharpe RM, Welsh M, 2010. Androgen action in the masculinization programming window and development of male reproductive organs. Int J Androl 33(2):279–287.20002220
Mylchreest E, Cattley RC, Foster PM D. 1998. Male reproductive tract malformations in rats following gestational and lactational exposure to di(n-butyl) phthalate: An antiandrogenic mechanism? Toxicol Sci 43:47–60.9629619
Mylchreest E, Sar M, Cattley RC, 1999. Disruption of androgen-related male reproductive development by di(n-butyl) phthalate during late gestation in rats is different from flutamide. Toxicol Appl Pharm 156:81–95.
Mylchreest E, Wallace DG, Cattley RC, 2000. Dose-dependent alterations in androgen-regulated male reproductive development in rats exposed to di(n-butyl) phthalate during late gestation. Toxicol Sci 55:143–151.10788569
NTP. 1995. Toxicity studies of dibutyl phthalate (CAS no. 84–74-2) administered in feed to F344/N and B6C3F1 mice. National Toxicology Program Toxicity Report Series, 30. Research Triangle Park, NC: National Toxicology Program/National Institutes of Health.
NTP. 2000. NTP-CERHR expert panel report on di-n-butyl phthalate. Alexandria, VA: Center for the Evaluation of Risks to Human Reproduction, U.S. Department of Health and Human Services. National Toxicology Program. NTP-CERHR-DBP-00.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. December 14, 2007.
Parks LG, Ostiby JS, Lambright CR, 2000. The plasticizer diethylhexyl phthalate induces malformations by decreasing fetal testosterone synthesis during sexual differentiation in the male rat. Toxicol Sci 58:339–349.11099646
Qiao L, Zheng L, Cai D. 2007. Study on the di-n-butyl phthalate and di-2-ethylhexyl phthalate level of girl serum related with precocious puberty in Shanghai. Wei Sheng Yan Jiu 36:93–95. [Chinese]17424861
Salazar V, Castillo C, Ariznavarreta C, 2004. Effect of oral intake of dibutyl phthalate on reproductive parameters of Long Evans rats and pre-pubertal development of their offspring. Toxicology 205:131–137.15458798
Schilling K, Kaufman W, Hildebrand B. 1992. Study on the oral toxicity of dibutyl phthalate in Wistar rats-administration via the diet over 3 months. BASF Corporation. Ludwigshafen, Germany. Microfiche No. OTS0535640; Document ID 86–920000903.
Wen Y, Liu S- D, Lei X, Yu-Shuang Ling, Yan Luo, and Qin Liu. 2015. Association of PAEs with Precocious Puberty in Children: A Systematic Review and Meta-Analysis Int J Environ Res Public Health. 12(12): 15254–15268.
Zacharewski TR, Meek MD, Clemons JH, 1998. Examination of the in vitro and in vivo estrogenic activities of eight commercial phthalate esters. Toxicol Sci 46:282–293.10048131

## Appendix C-3: Background Information for DNOP

DNOP is a synthetic chemical used as a plasticizer. DNOP can be found in carpetback coating, packaging films, medical tubing and blood storage bags, floor tile, wire, cables, adhesives, and also in cosmetics and pesticides. In plastics, DNOP is physically mixed into the product, rather than chemically bound. Therefore, it has the potential to migrate from the plastic matrix into the environment when conditions are ideal (ATSDR 1997).

### C-3.1 Toxicokinetics

No information was located regarding the toxicokinetics of DNOP in humans following any route of exposure or in animals following inhalation or dermal exposure. Oral studies in animals provide evidence of gastrointestinal absorption, but quantitative data are lacking on the rate and extent of absorption. A study of the distribution of DNOP in rats reported the identification of mono-octylphthalate in blood and testes within 1–24 hours (peak in plasma at 3 hours and at 6 hours in testes) after dosing, whereas a different study reported the identification of residues of DNOP in liver and adipose tissue. The metabolism of DNOP has been studied in vivo and in vitro, and the data indicate that, like most phthalate esters, DNOP can by hydrolyzed at one or both ester linkages to produce the monoester as well as phthalic acid (minor metabolite). As with other phthalates, subsequent oxidation of the remaining arylester to short-chain carboxyls, alcohols, and ketones has been demonstrated. Although one study seems to indicate that urine is the major elimination route of DNOP metabolites following oral exposure, no quantitative information on the rate and extent of excretion is available (ATSDR 1997).

### C-3.2 Health Effects

No information was located regarding health effects of DNOP in humans. Limited information is available in animal studies regarding the relevant endpoints for DNOP in this Interaction Profile mixture of chemicals. Dietary administration of approximately 2,000 mg/kg/day DNOP (only dose level tested) for 3, 10, or 21 days to rats induced a significant decrease in serum T_4_ (Hinton et al. 1986); serum levels of T_3_ were not affected. Morphological alterations in the thyroid included an increase in the number and size of lysosomes, enlargement of the Golgi apparatus, and damage to the mitochondria. A 13-week dietary study in rats reported reductions in size of the thyroid follicles and mild decreases in colloid density at 350 mg/kg/day in males and 403 mg/kg/day in females (Poon et al. 1997). The respective NOAELs were 37 and 41 mg/kg/day. No studies were located to determine whether exposure to DNOP might cause neurobehavioral effects in humans or in animals. In a preliminary assessment of the developmental toxicity of DNOP, gavage administration of doses of 9,780 mg/kg/day (only dose level tested) to mice on GDs 6–13 resulted in a significantly reduced number of pups born alive per litter and reduced pup weight gain (Hardin et al. 1987). However, the investigators noted that the statistical significance may have resulted more from exceptionally high concurrent control values for these two parameters than from chemical toxicity. In studies performed according to the NTP Continuous Breeding Protocol, administration of up to 7,460 mg/kg/day for 105 days DNOP to F_0_ generation mice or up to 8,640 mg/kg/day for 85–105 days to the F_1_ generation did not result in developmental alterations, as assessed by the number of live pups per litter, the proportion of pups born alive, pup sex ratio, or the live pup mean weight (Heindel et al. 1989; Morrissey et al. 1989; NTP 1985).

### C-3.3 Mechanisms of Action

No specific mechanism of toxicity has been identified for DNOP. DNOP does not appear to behave as a peroxisome proliferator, although such activity has been shown for other phthalate esters (ATSDR 1997).

### C-3.4 Health Guidelines

ATSDR (1997) derived an acute-duration oral MRL of 3 mg/kg/day for DNOP based on a LOAEL of 1,000 mg/kg/day for liver effects in rats administered DNOP by gavage daily for 14 days. The MRL was derived by dividing the LOAEL by an uncertainty factor of 300 (10 for animal to human extrapolation, 10 for human variability, and 3 for using a minimal LOAEL).

ATSDR (1997) derived an intermediate-duration oral MRL of 0.4 mg/kg/day for DNOP based on a NOAEL of 41 mg/kg/day for liver effects in rats exposed to DNOP in the diet for 13 weeks; the LOAEL was 403 mg/kg/day. The MRL was derived by dividing the NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

EPA (IRIS 2007) does not list an RfD of reference concentration (RfC) for DNOP.

NTP (2004) and IARC (2006) do not include DNOP in their listings. The EPA (IRIS 2007) has not classified DNOP as to its carcinogenicity.

### C-3.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The endpoints of concern for DNOP in this Interaction Profile mixture of chemicals are thyroid, neurobehavioral, and developmental. TTDs are derived below for endpoints that are not the basis of the MRL, using the methods described by ATSDR (2004a). The derivations are based primarily on data provided in ATSDR (1997), and in particular the LSE tables.

#### Thyroid Effects (Adults)

Sprague-Dawley rats exposed to up to 350 mg/kg/day DNOP (females) or up to 403 mg/kg/day (males) for 13 weeks in the diet showed mild changes in the thyroid consisting of reduction in the follicle size and decreased colloid density (Poon et al. 1997). These dose levels were also LOAELs for liver effects, and an intermediate-duration oral MRL was based on a NOAEL of 41 mg/kg/day for liver effects in female rats. A TTD_THYROID_ can be derived by applying an uncertainty factor of 100 (10 for animal to human extrapolation, 10 for human variability) to the NOAEL of 41 mg/kg/day. The TTD_THYROID_ for DNOP is 0.4 mg/kg/day. An additional uncertainty factor to account for extrapolation from intermediate-duration to chronic-duration exposure is not necessary based on observations made in 2-year studies in rats and mice exposed to the related chemical, DEHP (David et al. 2000a, 2000b). These studies reported no gross or microscopic changes in the thyroid following exposure to dietary levels of DEHP significantly higher than those used by Poon et al. (1997) with DBP. In the 90-day study, Poon et al. (1997) also tested DEHP at levels comparable to DNOP and reported comparable effects (reduction in the follicle size and decreased colloid density). Since no histological alterations were seen in the 2-year study with DEHP, it would appear that the thyroid alterations seen in the 90-day studies are transient and without long-lasting consequences for the animal.

#### Developmental Endocrine Effects

A preliminary assessment of the developmental toxicity of DNOP in mice reported a significantly reduced number of pups born a live per litter and reduced pup weight gain following maternal exposure to 9,780 mg/kg/day DNOP on GDs 6–13 (Hardin et al. 1987). These results were considered inconclusive due to the unusually high values for these parameters in the control group. Studies that followed a continuous breeding protocol, also in mice, reported no developmental alterations in offspring from mice treated with up to 8,640 mg/kg/day DNOP (Heindel et al. 1989; Morrissey et al. 1989; NTP 1985). This dose level constitutes a NOAEL for developmental effects. The lack of studies identifying a reliable

LOAEL for developmental effects for DNOP precludes derivation of a TTD_DEVELOPMENTAL_ for this chemical.

#### Neurobehavioral Effects

A TTD_NEUROBEHAVIORAL_ cannot be derived due to the lack of information on the potential neurobehavioral effects of DNOP.

#### Summary (TTDs for DNOP)

TTD_THYROID_ = 0.4 mg/kg/day

TTD_DEVELOPMENTAL_ = not derived

TTD_NEUROBEHAVIORAL_ = not derived

### C-3.6 References

ATSDR. 1997. Toxicological profile for di-n-octylphthalate. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2004. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
David RM, Moore MR, Finney DC, 2000a. Chronic toxicity of di(2-ethylhexyl)phthalate in rats. Toxicol Sci 55:433–443.10828276
David RM, Moore MR, Finney DC, 2000b. Chronic toxicity of di(2-ethylhexyl)phthalate in mice. Toxicol Sci 58:377–385.11099649
Hardin BD, Schuler RL, Burg JR, 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratog Carcinog Mutagen 7:29–48.2884741
Heindel JJ, Gulati DK, Mounce RC, 1989. Reproductive toxicity of three phthalic acid ester in a continuous breeding protocol. Fundam Appl Toxicol 12:508–518.2731665
Hinton RH, Mitchell FE, Mann A, 1986. Effects of phthalic acid esters on the liver and thyroid. Environ Health Perspect 70:195–210.3830106
IARC. 2006. Agents reviewed by the IARC monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. December 14, 2007.
IRIS. 2007. Integrated Risk I nformation System. U.S. Environmental Protection Agency. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. December 14, 2007.
Morrissey RE, Lamb JC, Morris RW, 1989. Results and evaluations of 48 continuous breeding reproduction studies conducted in mice. Fundam Appl Toxicol 13:747–777.2620795
NTP. 1985. Di-n-octylphthalate. Reproduction and fertility assessment in CD-1 mice when administered in feed. Research Triangle Park, NC: National Institute of Environmental Health Sciences, National Toxicology Program. NTP-85–140.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. December 14, 2007.
Poon R, Lecavalier P, Mueller R, 1997. Subchronic oral toxicity of di-n-octylphthalate and di(2-ethylhexyl)phthalate in the rat. Food Chem Toxicol 35:225–239.9146736

## Appendix C-4: Background Information for DEP

DEP is a synthetic chemical used as a plasticizer. DEP can be found in plastics used to manufacture toothbrushes, automobile parts, tools, toys, and food packaging. It is also used in cosmetics and pesticides. In plastics, DEP is physically mixed into the product, rather than chemically bound. Therefore, it has the potential to migrate from the plastic into the surrounding media when conditions are appropriate (ATSDR 1995).

### C-4.1 Toxicokinetics

No information was located regarding the toxicokinetics of DEP in humans with the exception of a report of 4.8% absorption after 72 hours post application to an in vitro preparation of human abdominal skin. Data in animals are limited. A single application of ^14^C-DEP to the skin of rats resulted in approximately 24% excretion of the applied radioactivity in the urine in 24 hours, indicating that at least, 24% was absorbed. In 7 days, total recovery of radioactivity in the urine and feces was about 50% of the applied dose. Dermally absorbed radioactivity derived from ^14^C-DEP was minimal (<0.5% of the applied dose) in tissues of rats 1 week after a single application, indicating virtually no absorption under the conditions of the study. No data were located regarding absorption, distribution, or excretion of DEP or metabolites in animals following inhalation or oral exposure. No in vivo studies were located regarding the metabolism of DEP in humans or animals. Hepatic and intestinal preparations from rats, ferrets, baboons, and humans showed that DEP is mono-deesterified and that the in vitro metabolism was qualitatively similar among the various preparations (ATSDR 1995).

### C-4.2 Health Effects

No information was located regarding health effects of DEP in humans. Limited information is available in animal studies regarding the relevant endpoints for DEP in this Interaction Profile mixture of chemicals. Exposure of rats to DEP up 3,710 mg/kg/day in the diet for 2 or 16 weeks had no significant effect on the gross or microscopic appearance of the pituitary, adrenals, or thyroid glands (Brown et al. 1978). Serum hormone levels were not measured in this study. No studies were located to determine whether exposure to DEP might cause neurobehavioral effects in humans or in animals. In a preliminary assessment of the developmental toxicity of DEP, gavage administration of doses of 4,500 mg/kg/day (only dose level tested) to mice resulted in no evidence of developmental effects, as assessed by survival, birth weight, and neonatal weight gain (Hardin et al. 1987). Dietary treatment of pregnant rats with 3,210 mg/kg/day DEP during GDs 6–15 resulted in fetuses with a significant increased number of skeletal variations, particularly rudimentary ribs on GD 20 (Field et al. 1993). This dose level also caused a significant reduction in maternal food consumption and weight gain during the treatment period; reduced food consumption was, according to the investigators, due to poor palatability of the food. The developmental NOAEL in this study was 1,910 mg/kg/day. In a continuous breeding study in mice, dietary administration of 3,250 mg/kg/day DEP to the parental generation did not alter the number of pups per litter, the proportion of pups alive, or the live pup birth weight (Lamb et al. 1987).

### C-4.3 Mechanisms of Action

No specific mechanism of toxicity has been identified for DEP. DEP appears to be a weak peroxisome proliferator compared with other phthalate esters (ATSDR 1995).

### C-4.4 Health Guidelines

ATSDR (1995) derived an acute-duration oral MRL of 7 mg/kg/day for DEP based on a minimal LOAEL of 2,000 mg/kg/day for reproductive effects in rats administered DEP by gavage for 2 days. The MRL was derived by dividing the LOAEL by an uncertainty factor of 300 (10 for animal to human extrapolation, 10 for human variability, and 3 for using a minimal LOAEL).

ATSDR (1995) derived an intermediate-duration oral MRL of 6 mg/kg/day for DEP based on a minimal LOAEL of 1,753 mg/kg/day for liver effects in rats exposed to DEP in the diet for 3 weeks. The MRL was derived by dividing the LOAEL by an uncertainty factor of 300 (10 for animal to human extrapolation, 10 for human variability, and 3 for using a minimal LOAEL).

EPA (IRIS 2007) derived an RfD of 0.8 mg/kg/day for DEP based on a NOAEL of 750 mg/kg/day for reduced growth rate, food consumption, and altered organ weight in rats in a subchronic feeding study. An uncertainty factor of 1,000 was used (10 for interspecies extrapolation, 10 for intraspecies extrapolation, and 10 for using a subchronic study).

NTP (2004) and IARC (2006) do not include DEP in their listings. The EPA (IRIS 2007) has classified DEP in Group D, not classifiable as to human carcinogenicity, based on no human data and inadequate data in animals. Based on updated guidelines for carcinogen risk assessment (EPA 2005), DEP is classified as a chemical for which there is inadequate information to assess carcinogenic potential.

### C-4.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The endpoints of concern for DEP in this mixture are thyroid, neurobehavioral, and developmental. TTDs are derived below for endpoints that are not the basis of the MRL, using the methods described by ATSDR (2004a). The derivations are based primarily on data provided in ATSDR (1995), and in particular the LSE tables.

#### Thyroid Effects

The only relevant information located is that from an intermediate-duration dietary study in rats. That study identified a NOAEL of 3,710 mg/kg/day (the highest dose level tested) for gross and microscopic histology of the endocrine glands, including the thyroid (Brown et al. 1978). Because a LOAEL was not identified, a TTD_THYROID_ cannot be derived.

#### Developmental Endocrine Effects

The highest developmental NOAEL for DEP below a LOAEL is 1,910 mg/kg/day from a gestational exposure study in rats (Field et al. 1993). In the group treated with doses of 3,210 mg/kg/day, there was a significant increase in the number of skeletal variations, particularly rudimentary ribs. However, since this dose level also caused a significant reduction in maternal food consumption and weight gain during the treatment period, and there is no evidence that the effect involved an endocrine-related mechanism, a TTD_DEVELOPMENTAL_ will not be derived.

#### Neurobehavioral Effects

A TTD_NEUROBEHAVIORAL_ cannot be derived due to the lack of information on the potential neurobehavioral effects of DEP.

#### Summary (TTDs for DEP)

TTD_THYROID_ = not available

TTD_DEVELOPMENTAL_ = not available

TTD_NEUROBEHAVIORAL_ = not available

### C-4.6 References

ATSDR. 1995. Toxicological profile for diethylphthalate. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2004. Guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Brown D, Butterworth KR, Gaunt IF, 1978. Short-term oral toxicity study of diethyl phthalate in the rat. Food Cosmet Toxicol 16:415–422.711065
EPA. 2005. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
Field EA, Price CJ, Sleet RB, 1993. Developmental toxicity evaluation of diethyl and dimethyl phthalate in rats. Teratology 48:33–44.8351646
Hardin BD, Schuler RL, Burg JR, 1987. Evaluation of 60 chemicals in a preliminary developmental toxicity test. Teratogenesis Carcinogen Mutagen 7:29–48.
IARC. 2006. Agents reviewed by the IARC monographs. Volumes 1–96. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/index.php. December 14, 2007.
IRIS. 2007. Integrated Risk Information System. U.S. Environmental Protection Agency. Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/index.html. December 14, 2007.
Lamb JC, Chapin RE, Teague RE, 1987. Reproductive effects of four phthalic acid esters in the mouse. Toxicol Appl Pharmacol 88:252–269.
NTP. 2004. Report on carcinogens. 11th ed. Research Triangle Park, NC: National Toxicology Program, U.S. Department of Health and Human Services, Public Health Service. http://ntp-server.niehs.nih.gov/ntp/roc/toc11.html. December 14, 2007.