# Appendix B Background Information for PBDEs

PBDEs are brominated organic compounds that were previously used as flame retardant additives in plastics, textiles, and other materials. As additives, they are physically mixed into product applications, rather than chemically bound. Therefore, they have the potential to migrate from materials into the environment when conditions are ideal. The primary source for Appendix B information is the ATSDR (2017) Toxicological Profile for Polybrominated Diphenyl Ethers (PBDEs). The chemical structures of PBDEs are described in Appendix D.

## B.1 Toxicokinetics

No studies are available regarding the extent or rate of absorption of PBDEs in humans (ATSDR 2017). Information regarding oral absorption in animals is available from studies of commercial PBDE mixtures and individual ^14^C-labeled tetra-, penta-, hexa-, and decaBDE congeners. As reviewed by ATSDR (2017), the most recent and best available estimates of oral absorption efficiencies following gavage administration in lipophilic vehicles indicate a range of 70–85% for tetra- (BDE-47), penta- (BDE-99, BDE-100), and hexa- (BDE-153, BDE-154) congeners, and 10–26% for decaBDE (BDE-209).

No studies were located that examined tissue distribution of PBDEs in humans following controlled oral exposure (ATSDR 2017). Evidence from studies evaluating maternal blood, cord blood, and breast milk from pregnant and nursing mothers exposed to environmental PBDEs (most likely via dust and food ingestion) indicated that PBDEs can transfer from the mother to the developing fetus or nursing infant (ATSDR 2017). In general, the tetra- and pentabrominated PBDEs have been the predominant congeners detected in maternal and cord serum samples and breast milk samples, but more recent studies assaying for a wider range of PBDE congeners found evidence for distribution of hepta-, octa-, or decaBDEs into cord serum and breast milk (ATSDR 2017).

Tissue distribution studies in animals orally exposed to ^14^C-labeled BDE-47, BDE-99, BDE-100, BDE-153, BDE-154, and BDE-209 indicated that decaBDE is distributed among tissues somewhat differently than tetra-, penta-, and hexaBDEs (ATSDR 2017). While lower-brominated BDE congeners are preferentially accumulated in adipose tissues following absorption and an initial wide distribution, absorbed decaBDE is less readily distributed to adipose tissues and appears to preferentially distribute to highly perfused tissues. Although less likely to partition to adipose tissues, decaBDE was still found in low quantities in adipose tissues in these studies, and has been shown to transfer from dams to fetuses and neonates from exposure during gestational and nursing periods (ATSDR 2017).

Oxidative hydroxylation of PBDEs is a principal metabolic transformation that occurs in humans and laboratory animals. Hydroxylated PBDEs have been identified in samples of human biological fluids, including blood and breast milk (ATSDR 2017). Hydroxylated PBDEs also have been identified in feces, carcasses, or bile of laboratory rodents exposed to ^14^C-labeled tetra-, penta-, hexa-, or decaBDEs (ATSDR 2017).

Information from in vivo toxicokinetic studies with rodents is inadequate to describe detailed metabolic pathways, but is adequate to propose that cytochrome P450s are involved in the formation of hydroxylated metabolites and hydroxylated debrominated metabolites of BDE-47, BDE-99, BDE-100, BDE-154, and BDE-209 (ATSDR 2017). Recent in vitro studies with human or rat liver microsomes or hepatocytes, and human or rat recombinant CYPs, provide more detailed information adequate for proposing metabolic pathways for BDE-47, BDE-99, and BDE-100 in humans showing CYP2B6 mediation for hydroxylation, debromination, and ether bond cleavage for BDE-47, hydroxylation and ether bond cleavage for BDE-99, and hydroxylation for BDE-100 (ATSDR 2017). However, no clear metabolic pathways were identified for BDE-153 or BDE-209 using these methods (ATSDR 2017).

Apparent half-lives of PBDE congeners in blood of PBDE-exposed workers during non-exposed vacation periods ranged from 15 days for BDE-209, 18–39 days for nonabrominated congeners, and 37–94 days for octabrominated congeners (ATSDR 2017). The detection of PBDEs in human breast milk samples indicates that elimination via milk is an elimination route for nursing women, but several studies examining PBDE concentrations during lactation do not provide a clear account of the degree to which PBDEs are cleared from the body during lactation (ATSDR 2017). Results from animal studies given single oral doses of ^14^C-labeled PBDE congeners or PBDE mixtures indicate that biliary excretion into the feces is the principal route of elimination in rats, and that the urine and feces are principal routes of elimination of orally absorbed PBDEs in mice (ATSDR 2017).

## B.2 Health Effects

Most health effects data on PBDEs are from studies of orally exposed laboratory animals and human studies in which the main exposure route was unknown, but expected to be oral (ATSDR 2017). Based on a comprehensive evaluation of available human and animal data, ATSDR (2017) concluded that the following are targets of concern from oral exposure to PBDEs:

- the developing nervous system expressed as changes in neurobehavior (decaBDE and lower-brominated PBDEs);
- the developing and mature thyroid (decaBDE and especially lower-brominated PBDEs);
- the pancreas and its importance in insulin regulation (decaBDE and lower-brominated PBDEs);
- the developing and mature liver (decaBDE and lower-brominated PBDEs); and
- the developing male and female reproductive systems (decaBDE and especially lower-brominated PBDEs).

Information on carcinogenic effects of PBDEs in animals is limited to results from three chronic bioassays of decaBDE mixtures in rats and mice. Significantly increased incidences of neoplastic liver nodules in rats and combined hepatocellular adenomas and carcinomas in mice were reported in one of the three chronic bioassays. No carcinogenicity studies of lower-brominated PBDEs were located in the available literature. An EPA (2008) IRIS Toxicological Review concluded that the available data for decaPBDE provided suggestive evidence of carcinogenic potential, principally based on no studies of cancer in humans exposed to decaBDE and evidence for increased incidences of neoplastic nodules in rats and hepatocellular adenomas and carcinomas (combined) in mice exposed to decaBDE. The NTP (2016) 14^th^ Report on Carcinogens does not contain a cancer classification for any PBDE.

## B.2 Mechanisms of Action

As reviewed by ATSDR (2017), the main targets of concern following PBDE exposure in humans are the developing nervous and reproductive systems, the developing and mature endocrine system, the liver, and the male reproductive system. Other potential targets are the female reproductive system, the adult nervous system, and the developing and adult immune system; however, ATSDR (2017) concluded that evidence for these endpoints is limited. ATSDR (2017) reviewed available mechanistic data related to general mechanisms (e.g., hepatic enzyme induction, AhR-mediated effects), endocrine disruption, and neurological effects and concluded that definitive mechanisms underlying these effects have not been elucidated. For other effects, including reproductive toxicity, immunotoxicity, and hepatotoxicity, only limited mechanistic data were available (ATSDR 2017).

General Mechanisms of Toxicity. The non-coplanar molecular characteristic of PBDEs, relative to the coplanar molecular characteristics of dioxins and dioxin-like compounds, accounts, at least in part, for marked differences in toxicological properties between dioxin-like halogenated compounds and PBDEs (ATSDR 2017). For example, structure-activity studies have shown that some PBDE congeners can bind to the AhR, although binding affinities and induction of AhR-mediated responses are very weak or negligible, particularly for commercial PBDE mixtures and environmentally relevant congeners (ATSDR 2017). A WHO panel of experts concluded that PBDEs had negligible ability to bind and activate the AhR and induce CYP1A1 activity, and as such, should not be included in the TEQ scheme for evaluating dioxin-like toxicity (Van den Berg et al. 2006). Further information on the mechanisms by which PBDEs induce neurotoxic or hepatic effects were not available (ATSDR 2017).

Endocrine Disruption Effects. As reviewed in detail by ATSDR (2017), mechanistic studies show that PBDEs and/or their metabolites are capable of acting as thyroid hormone transporters or receptors and are weakly estrogenic, anti-androgenic, anti-prostagenic, and anti-glucocorticogenic. However, these findings were not always consistent between different congeners, metabolites, and studies. Therefore, ATSDR (2017) concluded that mechanisms of endocrine disruption by PBDEs have not been fully elucidated.

Neurodevelopmental Effects. Developmental exposure to PBDEs has been associated with altered neurodevelopment and behavior later in life in both humans and animals (ATSDR 2017). As reviewed in detail by ATSDR (2017), mechanisms for these behavioral and cognitive effects have not been elucidated; however, proposed mechanisms include neuroendocrine disruption (including altered thyroid hormone homeostasis), alterations in neurotransmitter systems (cholinergic, dopaminergic, glutamatergic, and/or GABAergic), altered calcium homeostatic mechanisms, altered intracellular communication, oxidative stress, and cell death. Additionally, monohydroxylated metabolites are more potent than the parent PBDEs in several of the mechanistic assays, suggesting that bioactivation by oxidative metabolism contributes to the neurotoxic potential of PBDEs (see ATSDR 2017 for more in-depth discussion).

## B.4 Health Guidelines

ATSDR (2017) derived an intermediate-duration inhalation MRL of 0.006 mg/m^3^ for lower PBDEs based on a NOAEL of 1.1 mg/m^3^ for changes in thyroid hormones in rats intermittently exposed to a commercial octaBDE product for 13 weeks. The MRL of 0.006 mg/m^3^ was derived by dividing the NOAEL_HEC_ of 0.53 mg/m^3^ by an uncertainty factor of 30 (3 for species to species extrapolation with dosimetric adjustments and 10 for human variability) and a modifying factor of 3 (for an incomplete database reflecting a single study in one species). ATSDR (2017) did not derive acute- or chronic-duration inhalation MRLs for lower PBDEs due to the lack of appropriate data. Likewise, ATSDR (2017) did not derive inhalation MRLs for decaBDE for acute, intermediate, or chronic durations of exposure.

ATSDR (2017) derived an acute-duration oral MRL of 0.00006 mg/kg/day for lower PBDEs based on a LOAEL of 0.06 mg/kg/day for multiple effects observed in rat dams and offspring following a single exposure to 2,2’,4,4’,5-pentaBDE (BDE-99) on GD 6 via gavage, including thyroid effects (decreased serum T_4_ levels) in rat dams and developmental reproductive effects (male and female) and developmental neurobehavioral effects in adult F1 offspring (Kuriyama et al. 2005, 2007; Talsness et al. 2005). The MRL was estimated by dividing the 0.06 mg/kg LOAEL by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

ATSDR (2017) derived an intermediate-duration oral MRL of 0.000003 mg/kg/day for lower PBDEs based on a minimal LOAEL of 0.001 mg/kg/day for a 34% reduction in serum testosterone in male rats exposed to 2,2’,4,4’-tetraBDE (BDE-47) for 8 weeks via gavage (Zhang et al. 2013b). The MRL was estimated by dividing the 0.001 mg/kg/day m inimal LOAEL by an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

ATSDR (2017) did not derive a chronic-duration oral MRL for lower-brominated PBDEs due to insufficient data.

ATSDR (2017) derived an acute-duration oral MRL of 0.01 mg/kg/day for decaBDE based on a NOAEL of 1.34 mg/kg for neurobehavioral effects in 2–4-month-old mice following a single exposure to 2,2’,3,3’,4,4’,5,5’,6,6’-decaBDE (BDE-209) on PND 3 (Buratovic et al. 2014; Johansson et al. 2008). The MRL was estimated by dividing the 1.34 mg/kg NOAEL by an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability).

ATSDR (2017) derived an intermediate-duration oral MRL of 0.0002 mg/kg/day for decaBDE based on a minimal LOAEL of 0.05 mg/kg/day for a 12% increase in serum glucose in adult rats exposed to 2,2′,3,3′,4,4′,5,5′,6,6′-decabromodiphenyl ether (BDE-209) for 8 weeks via gavage (Zhang et al. 2013a). The change in serum glucose level was taken as a minimally adverse sign of insulin dysregulation observed at higher dose levels. The MRL was estimated by dividing the 0.05 mg/kg/day LOAEL by an uncertainty factor of 300 (3 for use of a minimal LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

ATSDR (2017) did not derive a chronic-duration oral MRL for decaBDE due to the lack of appropriate data. Data from the NTP (1986) 2-year dietary rat and mouse bioassays were not used as the basis for an MRL because the lowest tested dose was a LOAEL for precancerous liver lesions in male rats.

The EPA IRIS program derived oral RfDs for several individual PBDE congeners based on altered neurobehavior in 2–8-month-old mice following single exposure to individual congeners via gavage on PND 3 or 10 (IRIS 2008a, 2008b, 2008c, 2008d). An RfD of 0.0001 mg/kg/day was derived for 2,2’,4,4’,5-pentaBDE based on a BMDL_1SD_ of 0.29 mg/kg (IRIS 2008a); an RfD of 0.0001 mg/kg/day was derived for 2,2’,4,4’-tetraBDE based on a BMDL_1SD_ of 0.35 mg/kg (IRIS 2008b); an RfD of 0.0002 mg/kg/day was derived for 2,2’,4,4’,5,5’-hexaBDE based on a NOAEL of 0.45 mg/kg (IRIS 2008c); and an RfD of 0.007 mg/kg/day was derived for 2,2’,3,3’,4,4’,5,5’,6,6’-decaBDE based on a NOAEL of 2.22 mg/kg (IRIS 2008d). For each congener, an uncertainty factor of 3,000 (10 for intraspecies variability, 10 for interspecies variability, 10 for extrapolating from animals to humans and 3 for extrapolating from single-dose to lifetime exposure) was used.

The EPA IRIS program also derived oral RfDs for two commercial PBDE mixtures based on hepatic enzyme inductions in rats in 90-day gavage studies (IRIS 2002, 2003b). An RfD of 0.002 mg/kg/day was derived for a commercial pentaBDE mixture based on a NOAEL of 1.77 mg/kg/day (IRIS 2002) and an RfD of 0.003 mg/kg/day was derived for a commercial octaBDE mixture based on a NOAEL of 3.13 mg/kg/day (IRIS 2003b). For each commercial mixture, an uncertainty factor of 1,000 (10 for intraspecies variability, 10 for interspecies variability, and 10 for subchronic to chronic extrapolation) was used.

NTP (2016) and IARC (2016) do not include PBDEs in their listings. The EPA IRIS program has evaluated several individual congeners for carcinogenic potential, and determined that there is suggestive evidence of carcinogenic potential for 2,2’,3,3’,4,4’,5,5’,6,6’-decaBDE based on no human data and limited evidence of carcinogenicity in animals (IRIS 2008d) and inadequate information to assess carcinogenic potential for 2,2’,4,4’-tetraBDE, 2,2’,4,4’,5-pentaBDE, and 2,2’,4,4’,5,5’-hexaBDE (IRIS 2008a, 2008b, 2008c). An oral slope factor of 7×10^−4^ per mg/kg-day and a drinking water unit risk of 2×10^−8^ per μg/L were derived based on the incidence of hepatic tumors in rats (IRIS 2008d); quantitative estimates of carcinogenic risk are not available for tetra-, penta-, or hexaBDE congeners. The EPA IRIS program determined that commercial mixtures of nonaBDE, octaBDE, hexaBDE, pentaBDE, tetraBDE, triBDE, p,p’-diBDE, and p-BDE are not classifiable as to human carcinogenicity, based on no human data or animal data (2002a, 2002b, 2002c, 2003a, 2003b, 2003c, 2005, 2006). Based on updated guidelines for carcinogen risk assessment (EPA 2005), these compounds are classified as chemicals for which there is inadequate information to assess carcinogenic potential.

## B.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

The endpoints of concern for PBDEs in this Interaction Profile mixture of chemicals are thyroid, neurobehavioral, and developmental. TTDs are derived below for endpoints that are not the basis of the MRL, using the methods described by ATSDR (2004a). The derivations are based primarily on data provided in ATSDR (2017), in particular the LSE tables.

### Thyroid Effects (Adults)

DecaBDE. Dose-related increases in thyroid hyperplasia were reported for male Sprague-Dawley rats exposed to 80 and 800 mg/kg/day for 30 days (Norris et al. 1973, 1975b), but not in rats exposed to ≤90 mg/kg/day for 90 days, rats exposed to ≤8,000 mg/kg/day for 13 weeks, or mice exposed to ≤9,500 mg/kg/day for 13 weeks (IRDC 1976; NTP 1986). The occurrence of thyroid hyperplasia in the rats exposed to ≥80 mg/kg/day for 30 days could be related to the low purity c omposition of the older commercial decaBDE mixture tested by Norris et al. (1973, 1975a, 1975b) (i.e., 77.4% decaBDE, 21.8% nonaBDE, and 0.8% octaBDE), compared to the ≥94% decaBDE composition used in the NTP studies. In chronic-duration studies, thyroid follicular cell hyperplasia was increased at ≥3,200 mg/kg/day in male B6C3F1 mice that were exposed to ≥94% pure commercial decaBDE for 103 weeks (NTP 1986), making the 3,200 mg/kg/day dose level possibly a LOAEL for thyroid effects. Because none of these studies examined thyroid function, the true biological significance of the thyroid hyperplasia after repeated oral exposure to decaBDE is difficult to ascertain.

Decreased serum T_4_ and T_3_ levels were observed in male mice after 35-day exposures to 950 mg/kg/day decaBDE, but not to 750 mg/kg/day (Sarkar et al. 2015). Similarly, decreased serum T_4_ levels were observed in pregnant mice given 1,500 mg/kg/day, but not 750 mg/kg/day, on GDs 7–9 (Chi et al., 2011). Serum T_4_ levels were not changed in adult rats exposed to gavage doses up to 600 mg/kg/day decaBDE for up to 90 days (Lee et al. 2010; Van der ven et al. 2008; Wang et al. 2010, 2011; Zhou et al. 2001), and serum T_3_ levels were not changed in adult male rats exposed to decaBDE at doses up to 100 mg/kg/day via gavage for 90 days (Wang et al. 2010, 2011). Van der ven et al. (2008) reported significantly increased serum T_3_ levels in adult female, but not male, rats exposed to decaBDE at 60 mg/kg/day (but not at 30 mg/kg/day) via gavage for 28 days; however, this finding is inconsistent with evidence of decreased serum T_3_ levels in other studies of decaBDE and lower PBDEs. Additionally, Van der ven et al. (2008) indicate that there are “no observations to explain” elevated T_3_ levels. Therefore, this study was not considered for derivation of the oral TTD_THYROID_.

The lowest LOAEL for significant decreases in serum levels of thyroid hormones in adult animals among these oral studies is 950 mg/kg/day for decreased serum T_3_ and T_4_ levels in adult male mice (Sarkar et al. 2015). The associated NOAEL of 750 mg/kg/day serves as the point of departure (POD) for the oral TTD_THYROID_ for decaPBDE. Dividing the POD by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability) arrives at a value of 7.5 mg/kg/day decaBDE.

Lower PBDEs. The acute MRL of 0.00006 mg/kg/day is adopted for the oral TTD_THYROID_ for lower PBDEs. The acute-duration oral MRL is based on a LOAEL for decreased serum T_4_ levels in rat dams exposed to 0.06 mg/kg pentaBDE on GD 6 via gavage (as well as for developmental reproductive and neurobehavioral effects in adult F1 offspring) (ATSDR 2017). While this is a single-exposure study, the LOAEL is markedly lower than the lowest LOAELs for thyroid effects in available repeated-dose studies in adult animals exposed to lower PBDEs, which were ≥3 mg/kg/day (ATSDR 2017). Based on available data, the acute-duration study is the most sensitive study on which to base the oral TTD_THYROID_.

### Developmental Endocrine Effects

DecaBDE. Testicular lesions (increased incidence of slight/moderate vacuolization in interstitial cells) were observed in adult male offspring of mouse dams exposed to decaBDE at >10 mg/kg/day (lowest dose) GDs 0–17 (Tseng et al. 2013). Additional effects observed at 1,500 mg/kg/day included slight-severe vacuolization in seminiferous tubules, almost complete loss of spermatozoa and spermatids in seminiferous tubules, and increased abnormal sperm heads (Tseng et al. 2013). In other studies, no exposure-related changes were observed in male or female reproductive development in rats following gestational and lactation exposure to doses up to 1,000 mg/kg/day (anogenital distance [AGD], onset of puberty [preputial separation or vaginal opening], estrous parameters, and/or reproductive organ weight and histology) (Biesemeier et al. 2011; Fujimoto et al. 2011) or in mice following early postnatal exposure up to 30 mg/kg/day (AGD or onset of puberty) (Reverte et al. 2014; Rice et al. 2007).

Disruption in thyroid homeostasis occurred in developing animals following exposure to decaBDE, but the lowest LOAELs were higher than those observed for developmental reproductive effects. In young male rats exposed to decaBDE on PNDs 10–42, serum levels of T_3_ and T_4_ were significantly decreased at doses as low as 100 mg/kg/day, the lowest dose tested (Lee et al., 2010). In addition, decreased serum T3 levels were decreased in offspring exposed during gestation and lactation to doses as low as 146 mg/kg/day decaBDE in rats and 1,500 mg/kg/day in mice; no changes were observed in serum T_4_ or TSH (Fujimoto et al. 2011; Tseng et al. 2008).

The lowest LOAEL for altered endocrine development among these oral studies is 10 mg/kg/day for testicular lesions in adult male offspring of pregnant mice exposed on GDs 0–17 (Tseng et al. 2013). This LOAEL serves as the POD for the oral TTD_DEVELOPMENTAL_ for decaPBDE. Dividing the POD by an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability) arrives at a value of 0.01 mg/kg/day decaBDE.

Lower PBDEs. The acute MRL of 0.00006 mg/kg/day is adopted for the oral TTD_DEVELOPMENTAL_ for lower PBDEs. The acute-duration oral MRL is based on a LOAEL for developmental reproductive effects in adult F1 offspring of rat dams exposed to 0.06 mg/kg pentaBDE on GD 6 via gavage (as well as for decreased serum T_4_ levels in rat dams and neurobehavioral effects in adult F1 offspring) (ATSDR 2017). While this is a single-exposure study, the LOAEL is markedly lower than the lowest LOAELs for developmental reproductive effects reported in repeated-dose studies in developing animals (≥10.2 mg/kg/day) and lower than developmental thyroid effects in available pre- and peri-natal exposure studies (≥0.3 mg/kg/day) (ATSDR 2017). Based on available data, the acute-duration study is the most sensitive study on which to base the oral TTD_DEVELOPMENTAL_.

### Neurobehavioral Effects

DecaBDE. The acute MRL of 0.01 mg/kg/day is adopted for the oral TTD_NEUROBEHAVIORAL_ for decaBDE. The acute-duration oral MRL for decaBDE is based on a NOAEL of 1.34 mg/kg for neurobehavioral effects in 2–4-month-old mice following a single exposure to decaBDE on PND 3 (ATSDR 2017). While this is a single-exposure study, the lowest LOAEL for neurobehavioral changes following repeated exposures during early postnatal development was 20 mg/kg/day (delayed ontogeny of reflexes, increased locomotion), with an associated NOAEL of 6 mg/kg/day (Rice et al. 2007). Based on available data, the acute-duration study is the most sensitive study on which to base the oral TTD_NEUROBEHAVIORAL_.

Lower PBDEs. Animal studies reported neurodevelopmental effects following pre- and peri-natal exposures to lower-brominated PBDEs (tetra or penta BDEs) at doses ranging from 0.03 to 18 mg/kg/day, including neurobehavioral alterations, delayed ontogeny of reflexes, impaired learning, biochemical changes in the hippocampus, and decreased sociability (Blanco et al. 2013; Branchi et al. 2005; Cheng et al. 2009; Koenig et al. 2012; Ta et al. 2011; Woods et al. 2012). The lowest LOAEL value of 0.03 mg/kg/day is selected as the POD for the intermediate-duration TTD_NEUROBEHAVIORAL_ for lower PBDEs. Three studies identified this value as a LOAEL for neurobehavioral effects: (1) decreased performance in open field tests in PND 60 female offspring of mouse dams exposed to tetraBDE from premating day 28 to PND 2 (Ta et al. 2011); (2) decreased vocalization at PNDs 8–10 and decreased sociability at PND 72 in offspring of mouse dams exposed to tetraBDE from PMD 28 to PND 21 (Woods et al. 2012); and (3) transient changes in open field behavior in PND 34 offspring of mouse dams exposed to pentaBDE between GD 6 and PND 21 (Branchi et al. 2005). The intermediate-duration TTD_NEUROBEHAVIORAL_ of 0.00003 for lower PBDEs was derived by dividing the POD of 0.03 by an uncertainty factor of 1,000 (10 for using a LOAEL, 10 for animal to human extrapolation, and 10 for human variability).

### TTD Summary

DecaBDE

TTD_THYROID_: 7.5 mg/kg/day TTD_DEVELOPMENTAL_: 0.01 mg/kg/day TTD_NEUROBEHAVIORAL_: 0.01 mg/kg/day (acute MRL)

Lower PBDEs

TTD_THYROID_ = 0.00006 mg/kg/day (acute MRL)

TTD_DEVELOPMENTAL_ = 0.00006 mg/kg/day (acute MRL)

TTD_NEUROBEHAVIORAL_ = 0.00003 mg/kg/day

## B.6 References

Biesemeier JA, Ariano JM, Banasik M, 2011. Sample characterization: A priori to evaluating absorption, distribution, and metabolism. Toxicology 287(1–3):160–161..21669248
Blanco J, Mulero M, Heredia L, 2013. Perinatal exposure to BDE-99 causes learning disorders and decreases serum thyroid hormone levels and BDNF gene expression in hippocampus in rat offspring. Toxicology 308:122–128. 10.1016/j.tox.2013.03.010.23578391
Branchi I, Capone F, Vitalone A, 2005. Early developmental exposure to BDE 99 or Aroclor 1254 affects neurobehavioural profile: Interference from the administration route. Neurotoxicology 26(2):183–192. 10.1016/j.neuro.2004.11.005.15713339
Buratovic S, Viberg H, Fredriksson A, 2014. Developmental exposure to the polybrominated diphenyl ether PBDE 209: Neurobehavioural and neuroprotein analysis in adult male and female mice. Environ Toxicol Pharmacol 38(2):570–585. 10.1016/j.etap.2014.08.010.25194327
Cheng J, Gu J, Ma J, 2009. Neurobehavioural effects, redox responses and tissue distribution in rat offspring developmental exposure to BDE-99. Chemosphere 75(7):963–968. 10.1016/j.chemosphere.2009.01.004.19203780
Chi Y, Xia H, Su M, 2011. Metabonomic phenotyping reveals an embryotoxicity of decabrominated diphenyl ether in mice. Chem Res Toxicol 24(11):1976–1983. 10.1021/tx200300v.21995789
EPA. 2005. Guidelines for carcinogen risk assessment. Washington, DC: U.S. Environmental Protection Agency. EPA630P03001F.
EPA. 2008b. Toxicological review of decabromodiphenyl ether (BDE-209) (CAS No. 1163–19-5). In support of summary information on the Integrated Risk Information System (IRIS). Washington, DC: U.S. Environmental Protection Agency. http://www.epa.gov/iris/toxreviews/0035tr.pdf. December 19, 2014.
Fujimoto H, Woo GH, Inoue K, 2011. Impaired oligodendroglial development by decabromodiphenyl ether in rat offspring after maternal exposure from mid-gestation through lactation. Reprod Toxicol 31(1):86–94.20851758
IARC. 2016. Agents classified by the IARC monographs. Volumes 1–117. Lyon, France: International Agency for Research on Cancer. http://monographs.iarc.fr/ENG/Classification/List_of_Classifications.pdf. April 7, 2017.
IRDC. 1976. Decabromodiphenyl ether and octabromodiphenyl ether. A twenty-eight day toxicity study in rats with test data and cover letter. International Research and Development Corporation. Submitted to U.S. EPA under TSCA Section 8D. OTS0523322.
IRIS. 2002a. Pentabromodiphenyl ether; CASRN 32534–81-9. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0184_summary.pdf. April 7, 2017.
IRIS. 2002b. Hexabromodiphenyl ether; CASRN 36483–60-0. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0494_summary.pdf. April 10, 2017.
IRIS. 2002c. Tetrabromodiphenyl ether; CASRN 40088–47-9. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0493_summary.pdf. April 10, 2017.
IRIS. 2003a. Nonabromodiphenyl ether; CASRN 63936–56-1. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0495_summary.pdf. April 10, 2017.
IRIS. 2003b. Octabromodiphenyl ether; CASRN 32536–52-0. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0180_summary.pdf. April 10, 2017.
IRIS. 2003c. Tribromodiphenyl ether; CASRN 49690–94-0. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0492_summary.pdf. April 10, 2017.
IRIS. 2005. p,p'-Dibromodiphenyl ether; CASRN 2050–47-7. Chemical Assessment Summary. Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0491_summary.pdf. April 10, 2017.
IRIS. 2006. p-Bromodiphenyl ether; CASRN 101–55-3. Chemical Assessment Summary. Integrated Risk I nformation System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/subst/0490_summary.pdf. April 10, 2017.
IRIS. 2008a. Toxicological review of 2,2',4,4',5-pentabromodiphenyl ether (BDE-99) (CAS No. 60348–60-9). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1008tr.pdf. April 7, 2017.
IRIS. 2008b. Toxicological review of 2,2',4,4'-tetrabromodiphenyl ether (BDE-47) (CAS No. 5436–43-1). Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1010tr.pdf. April 7, 2017.
IRIS. 2008c. Toxicological review of 2,2',4,4',5,5'-hexabromodiphenyl ether (BDE-153) (CAS No. 68631–49-2). Integrated Risk I nformation System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/1009tr.pdf. April 7, 2017.
IRIS. 2008d. Toxicological review of decabromodiphenyl ether (BDE-209) (CAS No. 1163–19-5) Integrated Risk Information System. Washington, DC: U.S. Environmental Protection Agency. https://cfpub.epa.gov/ncea/iris/iris_documents/documents/toxreviews/0035tr.pdf. April 7, 2017.
Johansson N, Viberg H, Fredriksson A, 2008. Neonatal exposure to deca-brominated diphenyl ether (PBDE 209) causes dose-response changes in spontaneous behaviour and cholinergic susceptibility in adult mice. Neurotoxicology 29(6):911–919. 10.1016/j.neuro.2008.09.008.18930763
Koenig CM, Lango J, Pessah IN, 2012. Maternal transfer of BDE-47 to offspring and neurobehavioral development in C57BL/6J mice. Neurotoxicol Teratol 34(6):571–580. 10.1016/j.ntt.2012.09.005.23022914
Kuriyama SN, Talsness CE, Grote K, 2005. Developmental exposure to low dose PBDE 99: effects on male fertility and neurobehavior in rat offspring. Environ Health Perspect 113(2):149–154.15687051
Kuriyama SN, Wanner A, Fidalgo-Neto AA, 2007. Developmental exposure to low-dose PBDE-99: tissue distribution and thyroid hormone levels. Toxicology 242(1–3):80–90. 10.1016/j.tox.2007.09.011.17964054
Lee E, Kim TH, Choi JS, 2010. Evaluation of liver and thyroid toxicity i n Sprague-Dawley rats after exposure to polybrominated diphenyl ether BDE-209. J Toxicol Sci 35(4):535–545.20686340
Norris JM, Ehrmantraut JW, Gibbons CL, 1973. Toxicological and environmental factors involved in the selection of decabromodiphenyl oxide as a fire retardant chemical. Appl Polym Symp 22:195–219.
Norris JM, Kociba RJ, Humiston CG, 1975a. The toxicity of decabromo diphenyl and octabromo biphenyl as determined by subacute and chronic dietary feeding studies in rats. Toxicol Appl Pharmacol 33(1):170.
Norris JM, Kociba RJ, Schwetz BA, 1975b Toxicology of octabromobiphenyl and decabromodiphenyl oxide. Environ Health Perspect 11:153–161.126149
NTP. 1986. Toxicological and carcinogenesis studies of decabromodiphenyl oxide (CAS NO. 1163–19-5) in F344/N rats and B6C3F1 mice (feed studies). National Toxicology Program.
NTP. 2016. 14^th^ Report on carcinogens. Research Triangle Park, NC: U.S. D epartment of Health and Human Services, Public Health Service, National Toxicology Program. https://ntp.niehs.nih.gov/ntp/roc/content/listed_substances_508.pdf. April 7, 2017.
Reverte I, Domingo JL, Colomina MT. 2014. Neurodevelopmental effects of decabromodiphenyl ether (BDE-209) in APOE transgenic mice. Neurotoxicol Teratol 46:10–17. 10.1016/j.ntt.2014.08.003.25193018
Rice DC, Reeve EA, Herlihy A, 2007. Developmental delays and locomotor activity in the C57BL6/J mouse following neonatal exposure to the fully-brominated PBDE, decabromodiphenyl ether. Neurotoxicol Teratol 29(4):511–520.17482428
Sarkar D, Chowdhury JP, Singh SK. 2015. Effect of polybrominated diphenyl ether (BDE-209) on testicular steroidogenesis and spermatogenesis through altered thyroid status in adult mice. Gen Comp Endocrinol 10.1016/j.ygcen.2015.11.009.
Ta, Koenig CM, Golub MS, 2011. Bioaccumulation and behavioral effects of 2,2',4,4'-tetrabromodiphenyl ether (BDE-47) in perinatally exposed mice. Neurotoxicol Teratol 33(3):393–404. 10.1016/j.ntt.2011.02.003.21334437
Talsness CE, Shakibaei M, Kuriyama SN, 2005. Ultrastructural changes observed in rat ovaries following in utero and lactational exposure to low doses of a polybrominated flame retardant. Toxicol Lett 157(3):189–202. 10.1016/j.toxlet.2005.02.001.15917144
Tseng LH, Hsu PC, Lee CW, 2013. Developmental exposure to decabrominated diphenyl ether (BDE-209): effects on sperm oxidative stress and chromatin DNA damage in mouse offspring. Environ Toxicol 28(7):380–389. 10.1002/tox.20729.21626651
Tseng LH, Li MH, Tsai SS, 2008. Developmental exposure to decabromodiphenyl ether (PBDE 209): Effects on thyroid hormone and hepatic enzyme activity in male mouse offspring. Chemosphere 70(4):640–647.17698168
Van den Berg M, Birnbaum L, Denison M, 2006. The 2005 World Health Organization reevaluation of human and mammalian toxic equivalency factors for dioxins and dioxin-like compounds. Toxicol Sci 93(2):223–241.16829543
Van der Ven LT, van de Kuil T, Leonards PE, 2008. A 28-day oral dose toxicity study in Wistar rats enhanced to detect endocrine effects of decabromodiphenyl ether (decaBDE). Toxicol Lett 179(1):6–14.18495385
Wang F, Wang J, Dai J, 2010. Comparative tissue distribution, biotransformation and associated biological effects by decabromodiphenyl ethane and decabrominated diphenyl ether in male rats after a 90-day oral exposure study. Environ Sci Technol 44(14):5655–5660. 10.1021/es101158e.20536227
Wang F, Wang J, Hu G, 2011. Tissue distribution and associated toxicological effects of decabrominated diphenyl ether in subchronically exposed male rats. ISRN Toxicology 2011:989251.23724291
Woods R, Vallero RO, Golub MS, 2012. Long-lived epigenetic interactions between perinatal PBDE exposure and Mecp2308 mutation. Hum Mol Genet 21(11):2399–2411. 10.1093/hmg/dds046.22343140
Zhang Z, Sun ZZ, Xiao X, 2013. Mechanism of BDE209-induced impaired glucose homeostasis based on gene microarray analysis of adult rat liver. Arch Toxicol 87(8):1557–1567. 10.1007/s00204-013-1059-8.23640034
Zhang Z, Zhang X, Sun Z, 2013b. Cytochrome P450 3A1 mediates 2,2',4,4'-tetrabromodiphenyl ether-induced reduction of spermatogenesis in adult rats. PLoS ONE 8(6):e66301 http://www.plosone.org/article/info%66303Adoi%66302F66310.61371%66302Fjournal.pone.0066301. August 0066314, 0062014. 10.1371/journal.pone.0066301.23762486
Zhou T, Ross DG, DeVito MJ, 2001. Effects of short-term in vivo exposure to polybrominated diphenylethers on thyroid hormones and hepatic enzyme activities in weanling rats. Toxicol Sci 61(1):76–82.11294977