# Appendix A Background Information for CDDs

Results from studies of humans and animals given oral doses of 2,3,7,8-TCDD and other CDDs indicate that ingested CDDs can be well absorbed, that the efficiency of gastrointestinal absorption can be influenced by vehicle (i.e., absorption efficiencies are less for CDDs ingested with soil compared with CDDs ingested with an oil vehicle), and that CDDs with higher chlorination (e.g., octaCDDs) are poorly absorbed compared with less chlorinated CDDs such as tetraCDDs (ATSDR 1998). Inhalation and dermal exposure to CDDs are of lesser concern than oral exposure (because ingestion of CDDs in food is thought to be the principal route of exposure for the general population), but limited information from exposed human and animal studies indicate that CDDs can be absorbed by these routes. Information from studies of exposed humans and laboratory animals indicates that absorbed CDDs are distributed preferentially to fatty tissues and to a lesser extent, the liver (ATSDR 1998). CDDs can be transferred to the fetus across the placenta and to nursing infants via breast milk. CDDs are slowly metabolized in mammalian tissues via oxidation and reductive dechlorination reactions catalyzed by cytochrome P450 enzymes, followed by conjugation to more polar molecules such as glutathione and glucuronic acid (ATSDR 1998). The metabolism of 2,3,7,8-TCDD and related compounds is required for urinary and biliary excretion, and the rate of metabolism is thought to play a major role in regulating the rate of elimination (and detoxification) of these compounds (Van den Berg et al. 1994). The major routes of excretion of CDDs are via the bile and feces, whereas smaller amounts are excreted via the urine (ATSDR 1998). Monitoring of nursing mothers indicates that lactation can be a significant route of elimination of CDDs (ATSDR 1998). Results from studies of animals and humans exposed to 2,3,7,8-TCDD and related compounds indicate that CDDs and CDFs are slowly eliminated from the body; reported half-lives ranged from about 1 to 10 years in humans (ATSDR 1998; Aylward et al. 2006), close to a year in monkeys, and 10–100 days in laboratory rodents (ATSDR 1998; Van den Berg et al. 1994). Because of the long half-life of most of the halogenated aromatic hydrocarbons, the chemicals persist in the body for relatively long periods of time following single exposures.

## A.1 Health Effects

Evidence of endocrine disruption includes alterations in thyroid hormone levels, estrogenic and antiandrogenic reproductive alterations, and impaired development of the reproductive system. Decreases in T_4_ levels have been observed in rats following acute (0.1–0.3 μg/kg) or intermediate (0.05–0.8 μg/kg) exposures to 2,3,7,8-TCDD (ATSDR 1998). In humans, reproductive effects most likely associated with endocrine disruption include alterations in sex ratios primarily resulting from paternal exposure (ATSDR 1998; Mocarelli et al. 2000; Ryan et al. 2002), increased length of menstrual cycle resulting from prepubescent exposure (Eskenazi et al. 2002), earlier age of menopause (Eskenazi et al. 2005), decreased serum testosterone levels, increased serum follicle-stimulating hormone, and increased luteinizing hormone in males (ATSDR 1998). Estrogenic effects observed in adults of several animal species exposed to 2,3,7,8-TCDD include reduced fertility, litter size, and uterine weights, endometriosis, suppression of the estrous cycle (10 μg/kg), delayed puberty, and premature reproductive senescence (ATSDR 1998; Franczak et al. 2006; Yang et al. 2000). Antiandrogenic effects have been observed in males of several animal species and include loss of germ cells, degeneration of spermatocytes and spermatozoa, and decreased reproductive capability (ATSDR 1998).

Impaired development of the reproductive system has been observed in male and female offspring of rats exposed to 2,3,7,8-TCDD during gestation and/or lactation. In the female offspring, accelerated onset of constant estrus, shortened reproductive lifespan, and external urogenital malformations (clefting, hypospadias, vaginal thread, and delayed vaginal opening) were observed after a single dose of 1 μg/kg administered on GD 8 or 15 (ATSDR 1998). Alterations in androgen status (decreased plasma testosterone levels, delay in testes descent, delay in external signs of puberty, and decreased ventral prostate and seminal vesicle weights), testes and cauda epididymis weights, spermatogenesis (decreased daily sperm production, amount of mature sperm in cauda epididymis, and amount of sperm ejaculated), and demasculinization and partial feminization of sexual behavior have been observed in male offspring exposed; effects were observed at 0.064 μg/kg and higher administered on GD 15 (ATSDR 1998).

Perinatal exposure in animals results in structural malformations, functional alterations, decreased growth, and fetal/newborn mortality; many of the effects occurred at 2,3,7,8-TCDD doses that were not maternally toxic. In addition to the reproductive effects previously discussed, observed developmental effects include fetal/newborn mortality (≥0.7 μg/kg) or decreased survival (≥0.00064 μg/kg) (ATSDR 1998), decreased fetal and newborn body weight (≥0.7 μg/kg) (ATSDR 1998), increased incidence of cleft palate and skeletal anomalies (≥0.1 μg/kg) (ATSDR 1998), hydronephrosis (≥0.5 μg/kg) (ATSDR 1998), immunotoxicity (thymic atrophy and immunosuppression) (≥1.5 μg/kg) (ATSDR 1998), altered learning and memory (≥0.1 μg/kg) (Markowski et al. 2002; Seo et al. 1999, 2000), altered brain development (≥0.1 μg/kg) (Hojo et al. 2006; Hood et al. 2006; Nishijo et al. 2007; Zareba et al. 2002), and altered social behavior (≥0.00012 μg/kg) (ATSDR 1998).

Perinatal exposure in animals results in structural malformations, functional alterations, decreased growth, and fetal/newborn mortality; many of the effects occurred at 2,3,7,8-TCDD doses that were not maternally toxic. In addition to the reproductive effects previously discussed, observed developmental effects include fetal/newborn mortality (≥0.7 μg/kg) or decreased survival (≥0.00064 μg/kg) (ATSDR 1998), decreased fetal and newborn body weight (≥0.7 μg/kg) (ATSDR 1998), increased incidence of cleft palate and skeletal anomalies (≥0.1 μg/kg) (ATSDR 1998), hydronephrosis (≥0.5 μg/kg) (ATSDR 1998), immunotoxicity (thymic atrophy and immunosuppression) (≥1.5 μg/kg) (ATSDR 1998), altered learning and memory (≥0.1 μg/kg) (Markowski et al. 2002; Seo et al. 1999, 2000), altered brain development (≥0.1 μg/kg) (Hojo et al. 2006; Hood et al. 2006; Zareba et al. 2002), and altered social behavior (≥0.00012 μg/kg) (ATSDR 1998).

Studies of children of mothers with high background levels of CDDs, CDFs, and PCBs have found significant subclinical alterations in neurobehavioral outcomes, thyroid function, immune function, and liver enzyme levels (ATSDR 1998); however, the correlation coefficients were low, suggesting that only a small amount of the variance can be attributed to CDDs and related compounds, and it is not possible to determine the relative contribution of individual chemicals to the observed effects.

Recently, increased levels of thyroid stimulating hormone (TSH) in newborns exposed to TCDD in utero in the Seveso cohort indicated possible problems with regulation of thyroid hormone metabolism (Baccarelli et al. 2008). The authors reported that the mean TCDD levels correlated with TSH levels above or below 5 μU per mL serum. The 5 μU/mL standard is significant as it was established by WHO as an indicator of potential thyroid problems in neonates. The authors noted that higher TCDD exposures across all three zones of different contamination showed increased TSH concentrations. The group mean of 39 ppt TCDD was associated with TSH levels above the standard. Plasma TCDD was 5.2 ppt (95% CI 4.1–6.7) in newborns with b-TSH ≤ 5 μU/ml and 39.0 ppt (95% CI 8.9–173) in those with b-TSH > 5 μU/ml (p = 0.005).”

## A.2 Mechanisms of Action

CDDs produce a wide spectrum of biochemical effects in mammals that include induction of phase I enzymes (most notably CYP1A1 and CYP1A2) and phase II enzymes (e.g., UDP-glucuronosyl transferase and glutathione-S-transferase), reduction of levels of several growth factors (epidermal growth factor [EGF], transforming growth factor [TGF]-α, and TGF-β1) and increased expression of EGF receptor, and changes in thyroid hormone metabolism leading to lowered thyroid hormone levels (ATSDR 1998; De vito and Birnbaum 1994; Van den Berg et al. 1994). Many of the toxic and biological responses to CDDs are thought to be initially mediated through the binding of the parent compounds to a soluble intracellular protein, the AhR (ATSDR 1998; De vito and Birnbaum 1994; Van den Berg et al. 1994). The ligand-receptor complex is thought to be transported to the nucleus where it interacts with DNA and alters gene expression. For example, the induction of CYP1A1 by 2,3,7,8-TCDD is thought to be due to the interaction of the TCDD-AhR complex with nuclear genetic material leading to increased expression of the CYP1A1 gene (ATSDR 1998).

Alterations in gene expression have been linked to the development of some of the specific toxic responses to 2,3,7,8-TCDD and related compounds. General evidence that the AhR mediates the toxicity of CDDs comes from demonstrations that the toxicity of specific congeners is related to the affinity with which the compounds bind to the AhR and demonstrations that genetic differences in AhR binding affinity between strains of rodents are related to genetic differences in responsiveness to the toxic or biochemical effects of TCDD (Okey et al. 1994).

A working hypothesis of the molecular mechanism by which 2,3,7,8-TCDD induces cleft palate formation in rodents has received considerable research attention and illustrates how toxic effects may be mediated by CDDs through the AhR. In this mechanistic scheme, the TCDD-AhR’s transcriptional regulation of gene expression is thought to indirectly lead to reduced levels of several growth factors (EGF, TGF-α, and TGF-β1) and increased expression of the EGF receptor, which subsequently lead to altered medial cell proliferation in the developing palatal shelves (Abbott et al. 1994). TCDD-induced disruptions in the development of the kidney and male and female reproductive organs, observed in animal experiments, are also thought to be associated with TCDD-induced changes in levels of growth factors and receptors (ATSDR 1998). The molecular events between TCDD-induced changes in gene expression and reduced levels of growth factors remain to be elucidated (ATSDR 1998).

Changes in serum T_4_ levels from acute exposure to 2,3,7,8-TCDD has been postulated to involve TCDD induction of UDP-glucuronyltransferase, through the AhR, and subsequently increased metabolism and clearance of T_4_ (ATSDR 1998; Weber et al. 1995). From a comparison of responses to acute exposure to 2,3,7,8-TCDD among rats and different genetic strains of mice, however, Weber et al. (1995) have proposed that the AhR may not be the sole mediator of the toxicity of 2,3,7,8-TCDD. It has been postulated that some aspects of TCDD-disruption of thyroid hormone homeostasis may involve actions not related to AhR mediation, such as interference, by TCDD metabolites, of T_4_ binding to plasma transport proteins (ATSDR 1998).

## A.3 Health Guidelines

ATSDR (1998) has derived MRLs for acute-, intermediate-, and chronic-duration oral exposure to 2,3,7,8-TCDD.

The acute MRL of 0.0002 μg/kg/day was based on a no-observed-adverse-effect-level (NOAEL) of 0.005 μg/kg/day and a lowest-observed-adverse-effect level (LOAEL) of 0.01 μg/kg for immunological effects (increased susceptibility to influenza A-induced mortality) in mice given single gavage doses of 2,3,7,8-TCDD, an uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability), and a modifying factor of 0.7 (to adjust for the difference in higher bioavailability of 2,3,7,8-TCDD from an oil gavage vehicle than from food).

The intermediate MRL of 0.00002 μg/kg/day was based on a NOAEL of 0.0007 μg/kg/day and a LOAEL of 0.005 μg/kg/day for immunological effects (decreased thymus weight) in guinea pigs fed 2,3,7,8-TCDD in the diet for 90 days and an uncertainty factor of 30 (3 for extrapolation from animals to humans and 10 for human variability).

The chronic MRL of 0.000001 μg/kg/day was based on a LOAEL of 0.00012 μg/kg/day for neurodevelopmental effects (changes in social behavior in offspring) following the exposure of female monkeys to 2,3,7,8-TCDD in the diet throughout the mating period, gestation, and lactation and an uncertainty factor of 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR (1998) concluded that the results of epidemiology and animal studies indicate that 2,3,7,8-TCDD may be a human carcinogen. The International Agency Research on Cancer (IARC) (1997) classified 2,3,7,8-TCDD as a Group 1 compound - human carcinogen, based on limited evidence in humans and sufficient evidence in animals for the carcinogenicity of 2,3,7,8-TCDD. IARC (1997) considered the following in making this evaluation: “(i) 2,3,7,8-TCDD is a multi-site carcinogen in experimental animals that has been shown by several lines of evidence to act through a mechanism involving the AhR receptor; (ii) this receptor is highly conserved in an evolutionary sense and functions the same way in humans as in experimental animals; (iii) tissue concentrations are similar both in heavily exposed human populations in which an increased overall cancer risk was observed and in rats exposed to carcinogenic dosage regimens in bioassays.” Subsequently, the U.S. National Toxicology Program (NTP) listed TCDD as known to be a human carcinogen in the January 2001 addendum to the Ninth Report on Carcinogens with the rationale similar to that of IARC. IARC (1997) also concluded that “other polychlorinated dibenzo-p-dioxins are not classifiable as to their carcinogenicity to humans (Group 3),” based on inadequate evidence in humans and animals. The U.S. Environmental Protection Agency (EPA) Integrated Risk Information System (IRIS) does not list a weight-of-evidence classification for 2,3,7,8-TCDD or other CDDs.

## A.4 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to 2,3,7,8-TCDD were derived for thyroid, neurodevelopmental, and repro-developmental effects. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001, Section 2.3.2). The derivations are based on data provided in ATSDR (1998), and in particular, the oral Levels of Significant Exposure (LSE) table. Where the data were inadequate to derive a chronic oral TTD for a given endpoint, the chronic oral MRL is recommended as a conservative alternative that is protective of human health.

### Thyroid Effects

Thyroid effects of 2,3,7,8-TCDD have been well studied, albeit primarily by acute and intermediate exposure (ATSDR 1998). Several studies reported effects in animals (Kociba et al. 1978; NTP 1982; Van Birgelen et al. 1995). On February 17, 2012, EPA released the dioxin health hazard (re)assessment for noncarcinogenic effects (IRIS 2012). The chronic oral RfD was listed as 0.7 pg/kg/day. The RfD is based on two studies using the cohorts exposed in Seveso during the industrial accident. One of them reported increased TSH in neonates exposed in utero (Baccarelli et al. 2008). LOAELs of 0.02 ng/kg/day were modeled from internal doses (blood levels), and an uncertainty factor of 30 was used in the RfD derivation. The RfD of 0.7 pg/kg/day (0.7×10^−9^ mg/kg/day) can be used as a TTD_THYROID-DEVELOPMENTAL_ for 2,3,7,8-TCDD.

### Neurodevelopmental Effects

As described in Section A.4 above, the chronic oral MRL for 2,3,7,8-TCDD (ATSDR 1998) is based on neurodevelopmental effects (changes in social behavior in offspring) in monkeys. Therefore, the TTD_NEURODEVELOPMENTAL_ for 2,3,7,8-TCDD is the chronic oral MRL of 0.000001 μg/kg/day (1×10^−9^ mg/kg/day).

### Developmental Effects on Reproductive Endpoints

A number of studies have found that gestational exposure to 2,3,7,8-TCDD affects androgen levels, secondary sex organs, spermatogenesis, fertility, and sexual behavior in the offspring (ATSDR 1998). In 2012, EPA released the dioxin health hazard (re)assessment for noncarcinogenic effects (IRIS 2012). The chronic oral RfD was listed as 0.7 pg/kg/day. The RfD is based on two studies using the cohorts exposed in Seveso during the industrial accident (see also the thyroid effects). Decreased sperm count and mobility was found in men exposed to TCDD as boys (Mocarelli et al. 2008). LOAELs of 0.02 ng/kg/day were divided by an uncertainty factor of 30 to derive the RfD.

### Summary (TTDs for 2,3,7,8-TCDD)

TTD_THYROID_ = 0.00009 μg/kg/day (9×10^−8^ mg/kg/day)

Chronic oral MRL (based on neurodevelopmental effects) = 0.000001 μg/kg/day (1×10^−9^ mg/kg/day)

TTD_DEVELOPMENTAL_ = 0.00002 μg/kg/day (2×10^−8^ mg/kg/day)

## A.5 References

Abbott BD, Perdew GH, Birnbaum LS. 1994. Ah receptor in embryonic mouse palate and effects of TCDD on receptor expression. Toxicol Appl Pharmacol 126:16–25.8184424
ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins (Update). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Aylward LL, Brunet RC, Carrier G, 2006. Concentration-dependent TCDD elimination kinetics in humans: toxicokinetic modeling for moderately to highly exposed adults from Seveso, Italy, and Vienna, Austria, and impact on dose estimates for the NIOSH cohort. J Expo A nal Environ Epidemiol. 15(1):51–65.
Baccarelli A, Giacomini SM, Corbetta C, 2008. Neonatal thyroid function in Seveso 25 years after maternal exposure to dioxin. PLoS Medicine. 5:e161.18666825
De Vito MJ, Birnbaum LS. 1994. Toxicology of dioxins and related chemicals. In: Schecter A, ed. Dioxins and health. New York, NY: Plenum Press, 139–162.
Eskenazi B, Warner M, Micarelli P, 2002. Serum dioxin concentrations and menstrual cycle characteristics. Am J Epidemiol 156:383–392.12181109
Eskenazi B, Warner M, Marks AR, 2005. Serum dioxin concentrations and age at menopause. Environ Health Perspect 113:858–862.16002373
Franczak A, Nynca A, Valdez KE, 2006. Effects of Acute and Chronic Exposure to the Aryl Hydrocarbon Receptor Agonist 2,3,7,8-Tetrachlorodibenzo-p-Dioxin on the Transition to Reproductive Senescence in Female Sprague-Dawley Rats. Biol Reprod. 2006 74(1):125–130.16177221
Gray LE Jr., Ostby JS. 1995. In utero 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) alters reporductive morphology and function in female rat offspring. Tox Appl Pharm 133:285–294.
Hojo R, Zareba G, Kai JW, 2006. Sex-specific alterations of cerebral cortical cell size in rats exposed prenatally to dioxin. J Appl Toxicol. 26(1):25–34.16167324
Hood DB, Woods L, Brown L, 2006. Gestational 2,3,7,8-tetrachlorodibenzo-p-dioxin exposure effects on sensory cortex function. Neurotoxicology. 27(6):1032–1042.16839606
IARC. 1997. Polychlorinated dibenzo-para-dioxins. Lyon, France: International Agency for Research on Cancer. http://193.51.164.11/htdocs/monographs/vol69/dioxin.html.
Li X, Rozman KK. 1995. Subchronic effects of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and their reversibility in male Sprague-Dawley rats. Toxicology 97:133–140.7716779
Markowski VP, Cox C, Preston R, 2002. Impaired cued delayed alternation behavior in adult rat offspring following exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin on gestation day 15. Neurotoxicol Teratol 24(2):209–218.11943508
Mocarelli P, Gerthoux PM, Ferrari E, 2000. Paternal concentrations of dioxin and sex ratio of offspring. Lancet. 355(9218):1858–1863.10866441
Nishijo M, Kuriwaki J, Hori E, 2007. Effects of maternal exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin on fetal brain growth and motor and behavioral development in offspring rats. Toxicol Lett 173(1):41–47.17669605
NTP. 1982. Carcinogenesis bioassay of 2,3,7,8-tetrachlorodibenzo-p-dioxin (CAS no. 1746–01-6) in Osborne-Mendel rats and B6C3F1 mice (gavage study). Bethesda, MD: Carcinogenesis Testing Program, National Cancer Institute, National Institute of Health. Research Triangle Park, NC: National Toxicology Program. DHHS publication no. 82–1765.
NTP. 2001. Ninth annual report on carcinogens. U.S. Department of Health and Human Services, Public Health Services, Research Triangle Park, NC.
Okey AB, Riddick DS, Harper PA. 1994. The Ah receptor: Mediator of the toxicity of 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and related compounds. Toxicol Lett 70:1–22.8310450
Ryan JJ, Amirova Z, Carrier G. 2002. Sex ratios of children of Russian pesticide producers exposed to dioxin. Environ Health Perspect 110:A699–A701.12417498
Seo BW, Powers BE, Widholm JJ, 2000. Radial arm maze performance in rats following gestational and lactational exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Neurotoxicol Teratol. 22(4):511–519.10974589
Seo BW, Sparks AJ, Medora K, 1999. Learning and memory in rats gestationally and lactationally exposed to 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD). Neurotoxicol Teratol 21(3):231–239.10386826
van Birgelen APJM, Van der Kolk J, Fase KM, 1995. Subchronic dose-response study of 3,4,7,8-tetrachlorodibenzo-p-dioxin in female Sprague-Dawley rats. Toxicol Appl Pharmacol 132:1–13.7747272
Van den Berg M, De Jongh J, Poiger H, 1994. The toxicokinetics and metabolism of polychlorinated dibenzo-p-dioxins (PCDDs) and dibenzofurans (PCDFs) and their relevance for toxicity. Crit Rev Toxicol 24(1):1–74.8172651
Weber LW D, Lebofsky M, Stahl BU, 1995. Correlation between toxicity and effects on intermediary metabolism in 2,3,7,8-tetrachlorodibenzo-p-dioxin-treated male C257BL/6J and DBA/2J mice. Toxicol Appl Pharmacol 131:155–162.7878671
Yang JZ, Agarwal SK, Foster WG. 2000. Subchronic exposure to 2,3,7,8-tetrachlorodibenzo-p-dioxin modulates the pathophysiology of endometriosis in the cynomolgus monkey. Toxicol Sci. 56:374–381.10910996
Zareba G, Hojo R, Zareba KM, 2002. Sexually dimorphic alterations of brain cortical dominance in rats prenatally exposed to TCDD. J Appl Toxicol 22(2):129–137.11920938