# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

AGD: anogenital distance
Ah: aryl hydrocarbon
AhR: aryl hydrocarbon receptor
ATSDR: Agency for Toxic Substances and Disease Registry
BDE: Brominated diphenyl ether
BINWOE: binary weight-of-evidence
BTEX: benzene, toluene, ethylbenzene, and xylene
CDD: chlorinated dibenzo-p-dioxin
CDF: chlorinated dibenzofuran
DBP: di-n-butyl phthalate
DEP: Diethyl phthalate
DEHP: di-(2-ethylhexyl) phthalate
DNA: deoxyribonucleic acid
DNOP: Di-n-octyl phthalate
DRE: dioxin-responsive element
EGF: epidermal growth factor
EPA: Environmental Protection Agency
EROD: ethoxyresorufin O-deethylase
GD: gestation day
HI: Hazard Index
HQ: Hazard Quotient
IARC: International Agency Research on Cancer
IRIS: Integrated Risk Information System
kg: kilogram
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
MBP: monobutylphthalate
MEHP: monoethylhexylphthalate
mg: milligram
MRL: Minimal Risk Level
mRNA: messenger ribonucleic acid
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
PBDD: polybrominated dibenzo-p-dioxin
PBDE: polybrominated diphenyl ether
PBDF: polybrominated dibenzofuran
PBPD: physiologically based pharmacodynamic
PBTK: physiologically based toxicokinetic
PCB: polychlorinated biphenyl
PCDD: polychlorinated dibenzo-p-dioxin
PCDF: polychlorinated dibenzofurans
PCR: polymerase chain reaction
PND: postnatal day
POD: point of departure
PPAR: peroxisome proliferator-activated receptor
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
PVC: polyvinyl chloride
RfC: reference concentration
RfD: reference dose
T_3_: triiodothyronine
T_4_: thyroxine
TCDD: 2,3,7,8-tetrachlorodibenzo-p-dioxin
TEF: Toxic Equivalence Factor
TEQ: toxic equivalents
TGF: transforming growth factor
THR: thyroid receptor
TSH: thyroid stimulating hormone
TTD: target-organ toxicity dose
TTR: transthyretin
UDP: uridine-5’-diphosphate
U.S.: United States
WHO: World Health Organization
XRE: xenobiotic-responsive element
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to