# 5 List of References

*Cited in text

*Akleyev AV, Kossenko MM, Silkina LA, 1995. Health effects of radiation incidents in the Southern Urals. Stem Cells 13(Suppl 1):58–68.7488969
*Allenmand H, Pessayr D, Descatoire V, 1978. Metabolic activation of trichloroethylene into a chemically reactive metabolite toxic to the liver. J Pharmacol Exp Ther 204(3):714–723.633075
*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 1997. Toxicological profile for trichloroethylene. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2000. Toxicological profile for polychlorinated biphenyls (PCBs). Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001a. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001b. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001c. Toxicological profile for cesium. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001d. Toxicological profile for cobalt. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
*ATSDR. 2001e. Toxicological profile for strontium. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
Barton HA, Clewell HJ. 2000. Evaluating noncancer effects of trichloroethylene: Dosimetry, mode of action, and risk assessment. Environ Health Perspect 108(Suppl 2): 323–334.
Bartstra RW, Bentvelzen PAJ, Zoetelief J, 1998. Induction of mammary tumors in rats by single-dose gamma irradiation at different ages. Radiat Res 150:442–450.9768859
Brachmann J, Scherlag BJ, Rosenshtraukh LV, 1983. Bradycardia-dependent triggered activity: relevance to drug-induced multiform ventricular tachycardia. Circulation 68(4):846–856.6616779
Brandt I, Bergman A. 1987. PCB methyl sulphones and related compounds: Identification of target cells and tissues in different species. Chemosphere 8/9:1671–1676.
Brouwer A, Morse DC, Lans MC, 1998. Interactions of persistent environmental organohalogens with the thyroid hormone system: Mechanisms and possible consequences for animal and human health. Toxicol Ind Health 14(1–2):59–84.9460170
Bull RJ. 2000. Mode of action of liver tumor induction by trichloroethylene and its metabolites, trichloroacetate and dichloroacetate. Environ Health Perspect 108(Suppl 2):241–259.10807555
Carlson GP. 1973. Potentiation of carbon tetrachloride hepatotoxicityin rats by pretreatment with polychlorinated biphenyls. Toxicology 5:69–77.
Chapin RE, Phelps JL, Schwetz BA, 1989. Toxicology studies of a chemical mixture of 26 groundwater contaminants. Fund Appl Toxicol 13:388–398.
Chauhan KR, Kodavanti PRS, McKinney JD. 2000. Assessing the role of ortho-substitution on polychlorinated biphenyl binding to transthyretin, a thyroxine transport protein. Toxicol Appl Pharmacol 162:10–21.10631123
Cheek AO, Kow K, Chen J, 1999. Potential mechanisms of thyroid disruption in humans: Interaction of organochlorine compounds with thyroid receptor, transthyretin, and thyroid-binding globulin. Environ Health Perspect 107(4):273–278.
Chen G-g Cole AE, MacDermott AB. 1987. The influence of skeletal muscle on the electrical excitability of dorsal root ganglion neurons in culture. J Neurosci 7(8):2412–2422.3612247
Clewell HJ, Gentry PR, Covington TR, 2000. Development of a physiologically based pharmacokinetic model of trichloroethylene and its metabolites for use in risk assessment. Environ Health Perspect 108(Suppl 2):283–305.
Cogliano VJ. 1998. Assessing the cancer risk from environmental PCBs. Environ Health Perspect 106(6):317–323.9618347
Cox JL, Harrison SD. 1983. Correlation of metal toxicity with in vitro calmodulin inhibition. Biochem Biophys Res Comm 115(1):106–111.6615519
Crunelli V, Forda S, Kelly JS. 1984. The reversal potential of excitatory amino acid action on granule cells of the rat dentate gyrus. J Physiol 351:327–342.6379151
Darnerud PO, Morse D, Klasson-Wehler E, 1996. Binding of a 3,3', 4,4'-tetrachlorobiphenyl (CB-77) metabolite to fetal transthyretin and effects on fetal thyroid hormone levels in mice. Toxicology 106(1–3):105–114.8571380
Devi PU, Hossain M, Bisht KS. 1998. Effect of gamma radiation on the foetal haemopoietic system in the mouse. Int J Radiat Biol 74(5):639–646.9848283
Federman JH, Sachter JJ. 1997. Status asthmaticus in a paramedic following exposure to a roadside flare: A case report. J Emerg Med 15(1):87–89.9017492
Fischer JW. 2000. Physiologically based pharmacokinetic models for trichloroethylene and its oxidative metabolites.
Foster PP, Pearman I, Ramsden D. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- part II: Lung clearance of inhaled cobalt oxide in man. J Aerosol Sci 20(2):189–204.
Gehringer P, Proksch E, Szinovatz W. 1985. Radiation-induced degradation of trichloroethylene and tetrachloroethylene in drinking water. Int J Radiat Isot 36(4):313–314.
Germolec DR, Yang RSH, Ackermann MF, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. II. Immunosuppression in B6C3F mice. Fund Appl Toxicol 13:377–387.
Gonzalez-Reimers E, Rodriguez-Moreno F, Martinez-Riera A, 1999. Relative and combined effects of ethanol and protein deficiency on strontium and barium bone content and fecal and urinary excretion. Biol Trace Elem Res 68:41–49.10208655
Green T. 2000. Pulmonary toxicity and carcinogenicity of trichloroethylene: Species differences and modes of action. Environ Health Perspect 108(Suppl 2):261–264.10807556
*Greenland S, Salvan A, Wegman DH, 1994. A case-control study of cancer mortality at a transformer-assembly facility. Int Arch Occup Environ Health 66:49–54.7927843
Gu B, Liang L, Cameron P. 1997. Degradation of trichloroethylene (TCE) and polychlorinated biphenyls (PCBs) by Fe and Fe-Pd bimetals in the presence of surfactants and cosolvents. TCE and PCB degradation by zero-valence iron in the presence of surfactants. Abstract for 1997 International Containment Technology Conference and Exhibition (February 9–12, 1997, Tallahasee, Florida). NTIS DE97001366.
IARC. 1997. Polychlorinated dibenzo-para-dioxins. Lyons, France: International Agency for Research on Cancer. http://193.51.164.11/htdocs/monographs/vol69/dioxin.html. June 4, 1997.
*ICRP. 1979. Limits for intakes of radionuclides by workers. International Commission of Radiological Protection. ICRP Publication 30. New York: Pergamon Press. (Retrieval in Progress.)
*ICRP. 1990. 1990 Recommendations of the International Commission on Radiological Protection. International Commission of Radiological Protection. Annals of the ICRP. ICRP Publication No. 60.
ICRP. 1991. 1990 Recommendations of the International Commission on Radiological Protection. International Commission on Radiological Protection. Annals of the ICRP 21(1–3):1–195.
*ICRP. 1993. Age-dependent doses to members of the public from intake of radionuclides: Part 2. Ingestion dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 67.
ICRP. 1995. Age-dependent doses to members of the public from intake of radionuclides: Part 4. Inhalation dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 71.
*ICRP. 1996. Age-dependent doses to members of the public from intake of radionuclides: Part 5 Compilation of ingestion and inhalation dose coefficients. International Commission on Radiological Protection. Annals of the ICRP. ICRP Publication No. 72.
IRIS. 2000. Polychlorinated biphenyls. Integrated Risk Information System. http://www.epa.gov/iris/subst/0294.htm. August 3, 2000.
Johnson FN. 1972. Effects of alkali metal chlorides on activity in rats. Nature 238:333–334.4561839
Kaneko A, Pinto PH, Tachibana M. 1989. Transient calcium current of retinal bipolar cells of the mouse. J Physiol 410:613–629.2552084
Klewe WM, Herrmann CL, Houk JB. 1979. Effects of dietary polychlorinated biphenyls and polybrominated biphenyls on the renal and hepatic toxicities of several chlorinated hydrocarbon solvents in mice. J Toxicol Environ Health 5:605–615.226724
Korach KS, Sarver P, Chae K, 1988. Estrogen receptor-binding activity of polychlorinated hydroxybiphenyls: Conformationally restricted structural probes. Mol Pharmacol 33:120–126.3122017
Körbler VJ, Padovan I, Frank P. 1959. Die strahlentherapie des larynxcarcinoms mit radioaktivem kobalt, strontium, and cäsium. Radiol Clin 28:174–179.13668078
Koshimoto C, Takahashi S, Kubota Y, 1994. Evaluation of the effect of gamma-irradiation on fetal erythropoiesis in rats using blood cell volume as the index. J Radiat Res 35:74–82.7965992
*Kossenko MM, Hoffman DA, Thomas TL. 2000. Stochastic effects of environmental radiation exposure in populations living near the Mayak Industrial Association: Preliminary report on study of cancer morbidity. Health Phys 79(1):55–62.10855778
*Kossenko MM, Izhevsky PV, Degteva MO, 1994. Pregnancy outcome and early health status of children born to the Techa River population. Sci Total Environ 142:91–100.8178140
Kostial K, Kargačin B, Simonovi I. 1983. Efficiency of a composite treatment for mixed fission products in rats. J Appl Toxicol 3(6):291–296.6677650
Kreyling WG, Ferron GA, Haider B. 1986. Metabolic fate of inhaled Co aerosols in beagle dogs. Health Phys 51(6):773–795.3781852
Krishnan V, Safe S. 1993. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), and dibenzofurans (PCDFs) as antiestrogens in MCF-7 human breast cancer cells: Quantitative structure-activity relationships. Toxicol Appl Pharmacol 120(1):55–61.7685553
*Krnjević K, Lamour Y, MacDonald JF, 1979a. Effects of some divalent cations on motoneurones in cats. Can J Physiol Pharmacol 57(9):944–956.519537
*Krnjević K, Lamour Y, MacDonald JF, 1979b. Intracellular divalent cations and neuronal excitability. Can J Physiol Pharmacol 57(9):957–971.117890
Lash LH, Fisher JW, Lipscomb JC. 2000. Metabolism of trichloroethylene. Environ Health Perspect 108(Suppl 2):177–200.
Longcope C. 2000. The male and female reproductive systems in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner & Ingbar’s the thyroid: A fundamental and clinical text. Eighth edition. Philadelphia, PA: Lippincott Williams & Wilkins, 824–827.
Lonky E, Reihman J, Darvill T, 1996. Neonatal behavioral assessment scale performance in humans influenced by maternal consumption of environmentally contaminated Lake Ontario fish. J Great Lakes Res 22(2):198–212.
Lundkvist U. 1990. Clinical and reproductive effects of Clophen A50 (PCB) administered during gestation on pregnant guinea pigs and their offspring. Toxicology 6:249–257.
Matsumoto A. 1976. Effect of strontium on the epiphyseal cartilage plate of rat tibiae -- Histological and radiographic studies. Jpn J Pharmacol 26:675–681.1021603
*Mellow AM, Phillips TE, Silinsky EM. 1978. On the conductance pathway traversed by strontium in mediating the asynchronous release of acetylcholine by motor nerve impulses. Br J Pharmacol 63:229–232.667415
*Mentrard D, Vassort G, Fischmeister R. 1984. Calcium-mediated inactivation of the calcium conductance in cesium-loaded frog heart cells. J Gen Physiol 83:105–131.6319542
Messiha FS. 1978. Anti-depressant action of caesium chloride and its modification of chlorpromazine toxicity in mice. Br J Pharmacol 64:9–12.698485
Minamisawa T, Hirokaga K, Sasaki S, 1992. Effects of fetal exposure to gamma rays on aggressive behavior in adult male mice. J Radiat Res 33:243–249.1464856
Moon J. 1994. The role of vitamin D in toxic metal absorption: A review. J Am Coll Nutr 13(6):559–569.7706586
*Moslen MT, Reynolds ES, Szabo S. 1977. Enhancement of the metabolism and hepatotoxicity of trichloroethylene and perchoroethylene. Biochem Pharmacol 26:369–375.192239
*NCRP. 1999. Recommended screening limits for contaminated surface soil and review of factors relevant to site-specific studies. National Council on Radiation Protection and Measurements. NCRP Report No. 129.
Neiman A, Eisenmann DR. 1975. The effect of strontium, cobalt and fluoride on rat incisor enamel formation. Anat Rec 183(2):303–321.1200404
Neufeld EB, Boskey AL. 1994. Strontium alters the complexed acidic phospholipid content of mineralizing tissues. Bone 15(4):425–430.7917582
*NRC. 2001. Annual limits on intake (ALIs) and derived air concentrations (DACs) on radionuclides for occupational exposure. Effluent concentrations; concentrations for release to sewerage. Code of federal regulations. Chapter 1, Part 20, Appendix B. http://www.nrc.gov/NRC/CFR/PART020/part020-appb.html. May 23, 2001.
NTP. 1991. NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health. National Toxicology Program. NIH Publication No. 91–3124.
NTP. 1998. NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health. National Toxicology Program. NIH Publication No. 471.
Omdahl JL, DeLuca HF. 1972. Rachitogenic activity of dietary strontium. J Biol Chem 247(17):5520–5526.4341346
Özgür S, Sümner H, Kocoglu G. 1996. Rickets and soil strontium. Arch Dis Child 75:524–526.9014608
Padovan I. 1959. Our observations on the endolaryngeal application of radioactive isotopes. J Lar Otol 73(5):289–294.
Parham FM, Portier CJ. 1998. Using structural information to create physiologically based pharmacokinetic models for all polychlorinated biphenyls. Toxicol Appl Pharmacol 151:110–116.9705893
Patnode KA, Curtis LR. 1994. 2,2',4,4',5,5'- and 3,3',4,4',5,5'-Hexachlorobiphenyl alteration of uterine progesterone and estrogen receptors coincides with embryotoxicity in mink (Mustela vison). Fundam Appl Toxicol 127:9–18.
Patrick G, Batchelor AL, Stirling C. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- part VI: Lung clearance of inhaled cobalt oxide particles in SPF Fischer rats. J Aerosol Sci 20(2):249–255.
Rengasamy A, Kommineni C, Jones JA, 1999. Effects of hard metal on nitric oxide pathways and airway reactivity to methacholine in rat lungs. Toxicol Appl Pharmacol 157:178–191.10373402
Rhomberg LR. 2000. Dose-response analyses of the carcinogenic effects of trichloroethylene in experimental animals. Environ Health Perspect 108(Suppl 2):343–358.10807564
Rozanski GJ. 1987. Electrophysiological properties of automatic fibers in rabbit atrioventricular valves. Am J Physiol 253(4 Pt 2):H720–H727.2444116
Rylander L, Hagmar L. 1995. Mortality and cancer incidence among women with a high consumption of fatty fish contaminated with persistent organochlorine compounds. Scand J Work Environ Health 21:419–426.8824747
Rylander L, Stromberg U, Hagmar L. 1998b. Lowered birthweight among infants born to women with high intake of fish contaminated with persistent organochlorine compounds. Organohalogen Compounds 38:275–277.
Savitz DA, Sonnenfeld NL, Olshan AF. 1994. Review of epidemiologic studies of paternal occupational exposure and spontaneous abortion. Am J Ind Med 25:361–383.8160656
Snipes MB, Hahn FF, Muggenburg BA, 1979. Toxicity of ^90^Sr inhaled in a relatively insoluble form by beagle dogs, X. In: Inhalation Toxicology Research Institute, ed. Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 101–106.
Storey E. 1962. Strontium "rickets": Bone, calcium and strontium changes. Australas Ann Med 10:213–222.
Tandon L, Iyengar GV, Parr RM. 1998. A review of radiologically important trace elements in human bones. Appl Radiat Isot 49(8):903–910.9650262
Wartenberg D, Reyner D, Scott CS. 2000. Trichloroethylene and cancer: Epidemiologic evidence. Environ Health Perspect 108(Suppl 2):161–176.10807550
Widner TE, Ripple SR, Buddenbaum JE. 1996. Identification and screening evaluation of key historical materials and emission sources at the Oak Ridge Reservation. Health Phys 71(4):457–469.8830747
Wu C, Schaum J. 2000. Exposure assessment of trichloroethylene. Environ Health Perspect 108(2):359–363.10807565
Yamatani K, Saito K, Ikezawa Y, 1998. Relative contribution of Ca^2+^-dependent mechanism in glucagon-induced glucose output from the liver. Arch Biochem Biophys 355(2):175–180.9675024
Yang RSH, Goehl TJ, Brown RD, 1989. Toxicology studies of a chemical mixture of 25 groundwater contaminants. I. Chemistry development. Fund Appl Toxicol 13:366–376.