# SUMMARY

Review of Agency for Toxic Substances and Disease Registry’s (ATSDR) documents with site-specific information showed that stable and/or radioactive forms of cesium, cobalt, and strontium were found together at seven sites: Oak Ridge, Hanford Site, Brookhaven National Laboratory, Idaho National Environmental and Engineering Laboratory (INEEL), Nevada Test Site, Savannah River Site, and Lawrence Livermore Laboratory. Trichloroethylene was reported together with the radionuclides of cesium, cobalt, and strontium at Brookhaven National Laboratory and INEEL sites. Polychlorinated biphenyls (PCBs) were reported together with the radionuclides of cesium, cobalt, and strontium at Oak Ridge and INEEL sites. The purposes of this profile are: (1) to evaluate data (if available) on health hazards, and their dose-response relationships, from oral exposure to this five-component mixture; (2) to evaluate data on the joint toxic actions of components of this mixture; and (3) to make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

In the event of exposure, the primary route of exposure of nearby populations to these chemicals in soil is likely to be oral, resulting from contamination of soil and/or groundwater. Available reports of chemical use and prior chemical release concerning the sites of concern indicate that strontium, cobalt, and cesium radionuclides, rather than the stable forms of these metals, are of greatest concern for possible adverse health effects. While data on the effects of ingested strontium radionuclides are available, data on the toxic and/or carcinogenic effects of radiocobalt and radiocesium following oral exposure are lacking. However, as the most sensitive effects of the radionuclides are expected to come from emitted radiation, a reasonable estimate as to potentially sensitive targets for oral exposure to radiocobalt and radiocesium can be made from examining the toxicokinetics of the stable compounds, as well as the tissues that are sensitive to external exposure to cobalt or cesium radiation.

Recent ATSDR toxicological profiles are available for all five components that comprise the mixture (ATSDR 1997, 2000, 2001c, 2001d, 2001e). For the information on the mechanisms and health effects of radiation, the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999) was also consulted.

No studies were located that examined health effects in humans or animals exposed to mixtures exclusively containing strontium, cobalt, cesium, trichloroethylene, and PCBs, and no physiologically-based pharmacokinetic/pharmacodynamic (PBPK/PD) models for this mixture have been developed. As such, a component-based approach (ATSDR 2001a, 2001b), wherein the potential effect of individual components on other components in the mixture is evaluated, was used. The weight-of-evidence analysis indicates no evidence sufficient to support the existence of greater-than-additive or less-than-additive joint actions of the component pairs, where recommendations can be made at all. As data are lacking for the majority of the component pairs, the mechanisms of action for each component pair were also analyzed for evidence of joint toxic actions.

Component-based approaches that assume additive joint toxic action are recommended for exposure-based assessments of possible noncancer or cancer health hazards from oral exposure to strontium, cobalt, cesium, trichloroethylene, and PCBs, because there are no direct data available to characterize health hazards (and dose-response relationships) from the five-component mixture. The weight-of-evidence analysis indicated that data are inadequate to characterize the modes of joint action of the components, but the additivity assumption appears to be suitable in the interest of protecting public health since the components have several shared targets of toxicity (organs or organ systems that are individually affected by the components).

A target-organ toxicity dose (TTD) modification of the hazard index approach is recommended for conducting exposure-based assessments of noncancer health hazards. TTDs for several toxicity targets have been derived for each of the components, including TTDs for hematological, immunological, reproductive, neurodevelopmental, and hepatic effects. For assessment of cancer risks from joint toxic action of the mixture, a similar component-based approach is recommended that involves multiplication of intakes of the components by U.S. Environmental Protection Agency (EPA) cancer slope factors and summation of the resultant risk estimates.