# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

- Dr. Darrell R. Fisher, Ph.D.
  Senior Scientist
  Pacific Northwest National Laboratory
  229 Saint Street
  Richland, WA 99352
- Dr. Ronald L. Kathren, C.H.P., D.E.E.
  President, The Kathren Group, Inc.
  Professor of Pharmaceutical Science
  Washington State University
  137 Spring Street
  Richland, WA 99352
- Dr. Harihara Mehendale, Ph.D.
  Professor and Kitty DeGree Endowed Chair in Toxicology
  College of Pharmacy
  University of Louisiana at Monroe
  700 University Avenue
  Monroe, LA 71209-0495

All reviewers were selected in conformity with the conditions for peer review specified in CERCLA Section 104(I)(13).

Scientists from ATSDR have reviewed the peer reviewers’ comments and determined which comments will be addressed in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this mixture. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.