# Appendix E Background Information for PCBs

PCBs were manufactured in the United States between about 1930 and 1977, predominately for use as coolants and lubricants in electrical equipment such as transformers and capacitors due to their general inertness (they resist degradation by acids or alkali) and heat stability (ATSDR 2000). The manufacture of PCBs in the United States was stopped due to the evidence that they accumulate and persist in the environment and can cause toxic effects. Due to their biostability and lipophilicity, PCBs accumulate and concentrate in food chains; PCB concentrations in fatty tissue increase with increasing order of species in a food chain. There are 209 possible congeners of chlorinated biphenyls. PCBs were manufactured as complex mixtures of chlorinated biphenyls that varied in the degree of chlorination. For example, the commercial product Aroclor 1242, was a mixture of mono- through hepta-chlorinated biphenyls with an average chlorine content of 42%. Once released into the environment, commercial mixtures of PCBs undergo slow changes (predominately volatilization and biotransformation), so that patterns of PCBs in samples of food, human milk, or other environmental biota do not resemble any one particular commercial mixture (ATSDR 2000; Brouwer et al. 1998).

PCB congeners that have chlorines at the meta positions (3, 3', 5, or 5' carbons in the phenyl rings) or the para positions (4 or 4' carbons) can assume a co-planar geometry (i.e., the two rings can exist in the same plane), which is important in determining binding to the Ah receptor, a mediator of some of the toxic effects of PCBs. Increasing degrees of chlorination at the ortho positions (2, 2', 6, and 6' carbons) leads to increasing steric hindrance that prevents a co-planar geometry. In general, PCBs with no or only a single chlorine at an ortho position are co-planar, whereas congeners with two or more ortho chlorines are non-co-planar. PCBs without ortho chlorines generally account for only minor percentages of total PCBs in commercial PCB mixtures or samples of environmental biota (ATSDR 2000).

## E.1 Toxicokinetics

PCBs can be absorbed via the inhalation, oral, and dermal routes of exposure, and are expected to passively diffuse across cell membranes (ATSDR 2000). Data on absorption of inhaled PCBs are insufficient to estimate rates of absorption, but studies of humans and animals exposed to airborne PCBs provide qualitative information that inhaled PCBs can be absorbed (ATSDR 2000). Ingested PCBs appear to be efficiently absorbed based on studies of infants consuming PCBs in their mothers’ breast milk and studies of animals indicating retention percentages ranging from 60 to 100% of ingested doses. Studies of animals dermally exposed to doses of radiolabeled PCBs for 24 hours reported absorption efficiencies ranging from about 15 to 60% of administered doses based on monitoring of urine for several weeks post-dosing.

Once absorbed, PCBs tend to accumulate in lipid-rich tissues, but PCBs have been detected in other tissues as well (ATSDR 2000). For example, in rats given gavage doses of Aroclors 1254 or 1260, the highest concentrations of PCBs were found in fat tissue, followed by concentrations in kidney, liver, and brain; plasma and muscle tissue showed the lowest concentrations. PCB concentrations in human milk can be high relative to other tissue due to breast milk’s high fat content, and PCBs are efficiently transferred to children through breast-feeding. Results from animal studies support the importance of breast-feeding transfer to infants, and further indicate that PCBs can cross the placental barrier and enter the fetus. The amount of PCBs transferred to offspring is expected to be higher during lactation than during gestation. For example, in female rats administered PCBs before gestation, an average of 0.003% of the administered dose was transferred to the fetus, whereas 5% was transferred to sucklings (ATSDR 2000).

Rat studies indicate that different PCB congeners can accumulate to different degrees in different tissues. In rats given gavage doses of Aroclor 1254 (comprised of 2.1% mono-, di-, and tri-chlorinated PCB congeners, 19.1% tetra-, 49.6% penta-, 25.9% hexa-, 2.9% hepta-, and 0.5% octa- and nona-chlorinated PCB congeners), heavily chlorinated congeners (with 6–9 chlorines) accounted for greater percentages of total PCBs in analyzed tissues than in Aroclor 1254 itself (Kodavanti et al. 1998). Most PCBs in Aroclor 1254 have at least one ortho chlorine; PCBs without ortho chlorines account for <3% of PCBs in Aroclor 1254. Hexa- through nona-chlorinated congeners accounted for 29.3% of PCBs in Aroclor 1254, and, in contrast, 70, 66, and 49% of total PCBs in frontal cortical brain, liver, and fat tissues, respectively. Observations that lower chlorinated congeners or congeners with two adjacent unsubstituted carbons (i.e., at the meta and para positions; 3,4 or 3',4' positions) are metabolized more quickly than higher chlorinated congeners or congeners without adjacent unsubstituted carbons (ATSDR 2000; Parham and Portier 1998; Safe 1994) may provide at least a partial explanation of this differential tissue accumulation among PCB congeners.

Hydroxylated PCBs (i.e., phenolic PCBs) are the major metabolites of PCBs in humans and animals, and are formed either by direct catalysis or via arene oxide intermediates by several CYP oxygenase isozymes (ATSDR 2000; Expert Panel 1994; Safe 1994). Phenolic PCBs can be further hydroxylated to form dihydrodiols and catechols, or conjugated with glucuronides or sulfates, which facilitates excretion in bile or urine. Glutathione conjugates are formed from arene oxide intermediates by glutathione S-transferase catalysis and transported to the intestine in the bile (Safe 1994). In the intestine, cleavage of the carbon-sulfur bond by microbes leads to the formation of thiol intermediates which can be methylated and reabsorbed. Following reabsorption, the methylated thiols can be further oxidized to form methylsulfonyl-PCBs which have been proposed to be involved in respiratory toxic effects from PCB exposure (Bergman et al. 1992; Brandt and Bergman 1987). Non-ortho-substituted PCBs appear to be preferentially metabolized initially by CYP isozymes that are induced by 3-methylcholanthrene (e.g., CYP1A1 and 1A2), whereas PCBs with multiple ortho substitutions appear to be preferentially metabolized by phenobarbital-inducible isozymes (e.g., CYP2B2, 2B1, and 3A) (ATSDR 2000; Expert Panel 1994). Congeners with mono-ortho substitution appear to be metabolized by both types of CYP isozymes.

Comparison of congener concentrations in commercial PCB mixtures with concentrations in adipose tissue from exposed workers indicates that some PCB congeners are more readily transformed by metabolism than others (ATSDR 2000). For example, both 2,2',4,4',5,5'-hexachlorobiphenyl and 2,2',4,4',6,6'-hexachlorobiphenyl are found in commercial PCB mixtures and in environmental samples, but 2,2',4,4',5,5'-hexachlorobiphenyl was detected in the workers’ adipose tissue and 2,2',4,4',6,6'-hexachlorobiphenyl was not (ATSDR 2000). Results from rat studies indicate that the rate of metabolism decreases as the degree of chlorination on both phenyl rings increase and is dependent on the position of chlorine atoms on the phenyl ring (ATSDR 2000; Parham and Portier 1998; Safe 1984). Higher rates of hydroxylation are expected with PCBs that have two adjacent unsubstituted carbons in a phenyl ring at the 3,4 or 3',4' positions (i.e., meta-para unsubstituted carbons). For example, in humans exposed to PCBs, hexa- and hepta-chlorinated congeners were more slowly cleared from the blood than tetra- and penta-chlorinated congeners, and, among tetra- and penta-chlorinated congeners, those without adjacent unsubstituted carbons were more slowly cleared than those with adjacent unsubstituted carbons. In mice administered one of five tetrachlorobiphenyls, elimination half-lives for the congeners increased in the following order: 2,6,2',6' = 2,3,2',3' < 2,3,5,6 << 3,4,3',4' = 3,5,3',5, consistent with decreasing rate of metabolism in this sequence.

Different PCBs induce different spectrums of CYP isozymes (Connor et al. 1995; Hansen 1998). Commercial mixtures, such as Aroclor 1254 and 1242, induce both types of CYP isozymes. Co-planar PCBs without ortho substitution (e.g., the 3,3',4,4'-, 3,3',4,4',5-, and 3,3',4,4',5,5'-congeners) are among the most potent PCB inducers of CYP1A1/1A2 and have the greatest affinity for the Ah receptor. Mono-ortho PCBs with lateral substitutions (e.g., the 2,3,3',4,4'-, 2,3,4,4',5-, 2',3',4,4',5-, 2',3,4,4',5-, 2,3,3',4,4',5-, 2,3,3',4,4',5'-, 2,3',4,4',5,5'-, and 2,3,3',4,4',5,5'- congeners) induce both CYP1A1/1A2 and CYP2B1/2B2 isozymes and have less affinity for the Ah receptor than the non-ortho PCBs. Some diortho PCBs induce both types of CYP isozymes and have less affinity for the Ah receptor than the mono-ortho congeners (e.g., the 2,2',3,3',4,4'-, 2,2',3,4,4',5'-, and 2,2',3,3',4,4',5-). In contrast, most congeners with multiple ortho chlorines and one or two para chlorines (e.g., 2,2',4,4'-, 2,2',4,4',5-, 2,2',4,5,5'-, 2,3,3',4',6-, 2,2',4,4',5,5'-, 2,3,3', 4',5,6-, 2,2',3,4,4',5',6-, 2,2',3,4',5,5',6-, 2,2',3,3',4,4',5,5'-, and 2,2',3,3',4,5,5',6'-congeners) induce only the CYP2B1/2B2 and 3A isozymes and essentially do not bind to the Ah receptor.

In general, PCB congeners display a wide range of elimination rates that have been demonstrated in several cases to be associated with the rates at which they are metabolized (i.e., more rapidly metabolized PCBs are more rapidly excreted) (ATSDR 2000). Studies with animals given parenteral or oral doses of PCB mixtures or individual PCBs indicate that excretion of PCBs and their metabolites occurs via feces and urine with much greater amounts excreted in the feces (ATSDR 2000). For example, within 42 days of administration of an intravenous dose of radiolabeled 3,3',5,5'-tetrachlorobiphenyl (a PCB that is more rapidly metabolized than other more highly chlorinated PCBs) to rats, 80% of the dose was excreted in the feces and 6.1% was excreted in the urine. Less than 10% of radioactivity in bile, feces, and urine was parent compound. Within 40 weeks of administration of an intravenous dose of a poorly metabolized PCB (2,2',4,4',5,5'-hexachlorobiphenyl), rats excreted 16% of the dose in feces and 0.8% in the urine. Another significant route of elimination is breast milk; it has been estimated that an infant in an industrialized country may accumulate about 7% of its lifetime PCB body burden during 6 months of breast feeding (ATSDR 2000).

## E.2 Health Effects

Associations have been noted between occupational exposure to commercial mixtures of PCBs and several health effects including chloracne and other skin changes; various hepatic effects including increased serum levels of liver enzymes and lipids, induction of drug-metabolizing enzymes, and hepatomegaly; decreased birth weight in offspring (of occupationally exposed mothers); and eye irritation (Safe 1994; Swanson et al. 1995).

Studies of cancer mortality in occupationally exposed workers have not found consistent or strong evidence of carcinogenicity, but findings of increased incidence of liver tumors in studies of rats exposed to commercial PCB mixtures suggest that PCBs are probable human carcinogens (ATSDR 2000; Safe 1994). IARC (1987) classified the human evidence as limited, whereas EPA (IRIS 2000) classified the human evidence as inadequate, but suggestive. Some cohort mortality studies of workers exposed during capacitor manufacturing and repair found increased risk for liver, biliary tract, gall bladder, and/or intestinal cancers, but statistically significant increases were not observed in all studies, and clear demonstrations of increasing risk with increasing exposure indices were not found (ATSDR 2000). Most case-control studies examining possible associations between breast cancer in women and concentrations of PCBs in breast tissue or blood found no statistically significant association (ATSDR 2000; Swanson et al. 1995).

Two incidences of consumption of PCB-contaminated cooking oil, one in Japan (the “Yusho” incident) and the other in Taiwan (the “Yucheng” incident), were associated with acne and skin pigmentation in adults and abnormalities in offspring including dark pigmentation of the skin, lower birth weight, and slower development (ATSDR 2000; Safe 1994; Swanson et al. 1995). These incidents are usually cited in discussion of the health effects of PCBs, but it is generally thought that the health effects were due primarily to polychlorinated dibenzofurans rather than PCBs (ATSDR 2000; Expert Panel 1994; Safe 1994; Swanson et al. 1995).

Studies of people and animals with diets containing Great Lakes fish (contaminated with PCBs and other biopersistent chemicals) provide suggestive evidence that frequent dietary consumption of contaminated fish by child-bearing-aged women may be associated with subtle neurobehavioral effects in their children, but no consistent evidence for associations with impaired reproduction, immune capabilities, or physical birth defects (ATSDR 2000). In one prospective study, limited evidence was presented relating maternal PCB exposure levels and deficits in neonatal behavioral development, short-term memory during infancy, and general intellectual ability in early school years (Jacobson 1985; Jacobson and Jacobson 1996; Jacobson et al. 1984, 1990). Statistically significant relationships between maternal PCB exposure levels (cord blood concentrations of PCBs with 7–9 chlorines) and deficits in neonatal behavioral development also were found in another more recent prospective study (Lonky et al. 1996; Stewart et al. 1999, 2000). Studies of people and animals with diets containing contaminated Baltic Sea fish provide suggestive evidence that contaminated fish consumption may be associated with impaired immunological competence or low birth weight, but do not clearly demonstrate dose-response relationships for the potential health hazards (Ross et al. 1995; Rylander and Hagmar 1999; Rylander et al. 1995, 1996, 1998a, 1998b; Svensson et al. 1994). Results from a North Carolina (Gladen and Rogan 1991; Gladen et al. 1988; Rogan et al. 1986a, 1986b, 1987) and a Dutch study (Huisman et al. 1995a, 1995b; Koopman-Esseboom et al. 1994, 1996; Patandin et al. 1998a, 1998b, 1999) of breast-fed children provide some evidence that exposure to PCBs in human breast milk at exposure levels in the upper range of background levels or exposure to PCBs in utero may result in mild neurodevelopmental delays in some children. It is plausible that exposure to PCBs may have contributed to these associations, but these studies of possible health effects from environmental exposure to PCB-containing complex mixtures cannot determine with certainty which chemicals may cause the effects or determine possible interactions that may occur among the components.

Oral exposure to commercial mixtures of PCBs has been demonstrated to produce a wide array of toxic effects in animals including:

1. inhibition of body weight gain or body weight loss in rats, rabbits, monkeys, or minks after acute, intermediate, or chronic exposure (ATSDR 2000; Safe 1994);
2. increased porphyrin levels in liver, urine, or kidneys in rats after intermediate exposure (ATSDR 2000; Safe 1994);
3. dermal effects including acne, alopecia, or finger- and toenail loss in monkeys or rats exposed for intermediate or chronic exposure (ATSDR 2000);
4. induction of hepatic levels of Phase I (CYP oxygenases) and Phase II (e.g., ridine-5'-diphosphate glucuronyltransferases [UDP-GT]) enzymes (ATSDR 2000; Safe 1994);
5. increased liver weight, increased serum cholesterol, or degenerative liver changes (e.g., fatty changes, necrosis) in rats after acute exposure, in monkeys, rats, or mice after intermediate exposure, and in monkeys or rats after chronic exposure (ATSDR 2000);
6. altered thyroid hormone levels (e.g., T_4_), histology, or weight in adult rats after acute exposure, in rats or mice after acute in utero exposure, and in adult rats after intermediate exposure (ATSDR 2000; Safe 1994);
7. fetal toxicity and decreased fetal survival in rats and hydronephrosis in mice exposed for acute durations in utero, fetal toxicity and decreased survival in monkeys, rats, mice, rabbits, guinea pigs, or minks exposed for intermediate durations, or in monkeys exposed for chronic durations (ATSDR 2000);
8. altered neurobehavior and/or brain chemistry in adult rats after acute exposure or adult monkeys or rats after intermediate exposure (ATSDR 2000);
9. altered neurobehavior in rats or mice after acute in utero exposure, in offspring of rats or mice exposed for intermediate durations, or in offspring of monkeys exposed for chronic durations (ATSDR 2000);
10. impaired reproductive function or altered reproductive organ weight or structure in adult monkeys, rats, mice, or mink after intermediate exposure, or in adult monkeys after chronic exposure (ATSDR 2000);
11. altered reproductive function or reproductive organ weight or structure in rats after acute in utero exposure (ATSDR 2000);
12. decreased immunological responsiveness (e.g., increased mortality from microbial infection or decreased antibody production in response to foreign blood cells) and/or altered organ weights or histopathology of thymus or spleen in monkeys, rats, mice, rabbits, or guinea pigs exposed for intermediate durations and in monkeys exposed for chronic durations (ATSDR 2000); and
13. increased incidence of liver tumors in rats exposed for chronic durations, and promotion (but not initiation) of preneoplastic lesions and tumors in the liver and lung of rats and mice following initiation by other carcinogens such as N-nitrosodiethylamine (ATSDR 2000).

## E.3 Mechanisms of Action

Mechanisms by which the broad array of toxic effects observed in animals orally exposed to PCB mixtures develop are incompletely understood, but there is evidence to suggest that PCB congeners differ qualitatitively and quantitatively in biological activities and that multiple and diverse mechanisms are involved in responses to PCB mixtures. Research in the 1970s and 1980s focused on mechanistic similarities between PCBs and chlorinated dibenzo-p-dioxins (CDDs) involving initial mediation of effects by the Ah receptor (Poland and Knutson 1982; Safe 1990, 1994), but research through the 1990s has found increasing evidence for the involvement of alternative mechanisms for several PCB-induced effects (Chauhan et al. 2000; Cheek et al. 1999; Fischer et al. 1998; Hansen et al. 1998; Harper et al. 1993a, 1993b; Safe 1994; Tilson and Kodavanti 1998). An in-depth and all-inclusive review of the many recent and ongoing research efforts regarding PCB mechanisms of action is outside of the scope of this profile; rather, an overview of this large body of research is presented with the intent of providing information relevant to public health issues.

### PCB Effects Involving Ah-receptor Dependent Mechanisms

#### INDUCTION OF HEPATIC CYP1A OXYGENASES AND PHASE II ENZYMES

PCBs induce hepatic Phase I enzymes (CYP oxygenases) and Phase II enzymes (e.g., UDP glucuronyl-transferases, epoxide hydrolase, or glutathione transferase) to varying degrees and specificities (Connor et al. 1995; Hansen et al. 1998; Safe 1994). Demonstration of relationships between PCB molecular structure and induction of CYP isozymes has provided a framework within which much mechanistic research has been conducted. In general, commercial mixtures of PCBs induce both 3-methylcholanthrene-type (CYP1A1 and 1A2) and phenobarbital-type (CYP2B1, 2B2, and 3A) CYPs. Strong structure-activity relationships have been demonstrated between CYP1A1/1A2 induction in rodents and non-ortho and mono-ortho PCBs which can assume a coplanar molecular configuration and bind to the Ah receptor (Connor et al. 1995; Hansen et al. 1998; Safe 1994). In structure-activity studies of CYP1A induction in hepatocytes from Cynomolgus monkeys by 20 PCBs varying in degree and pattern of chlorine substitution (4–7 chlorines), the most potent inducers were without ortho chlorines (van der Burght et al. 1999). Many PCBs with ortho chlorines (mono-, di-, tri-, and tetra-ortho congeners) displayed no CYP1A induction activity, but a few mono-ortho and multiple-ortho congeners displayed activities that were about 1,000- and 10,000-fold less than the most potent non-ortho congeners, respectively (van der Burght et al. 1999). A working mechanistic hypothesis involves initial binding of coplanar PCBs to the Ah receptor in the cytosol of target cells, transport of the ligand-receptor complex to the nucleus, and subsequent changes in gene expression (e.g., induction of CYP1A1/1A2) leading to toxic responses via subsequent molecular mechanisms that are largely unexplored. Support for this hypothesis comes from the similarity in the array of PCB effects compared with the array produced by 2,3,7,8-tetrachlorodibenzo-p-dioxin (TCDD) and related halogenated aromatic hydrocarbons via initial Ah-receptor mediation, results from in vitro binding studies, and results from congener-specific in vivo studies of specific endpoints (e.g., enzyme induction and down regulation, body weight, and immunological responses to sheep red blood cells) in mouse strains and rat genders differing in responsiveness to Ah-receptor mediation (Hori et al. 1997; Safe 1990, 1994).

The complexity of Ah-receptor mediated effects on hepatic enzyme levels is illustrated by results from a study with mouse strains differing in Ah-receptor responsiveness and three PCB congeners (Hori et al. 1997). Ah-responsive (C57BL/6) and Ah-non-responsive (DBA/2) mice were given single intraperitoneal doses of 3,3',4,4',5-pentachlorobiphenyl, a congener with high Ah-receptor affinity, 3,3',4,4'-tetrachlorobiphenyl, a congener with lesser affinity, and 2,2',5,5'-tetrachlorobiphenyl, a low-affinity ligand. Only the high-affinity 3,3',4,4',5-congener produced body weight wasting in the dose range tested (up to 50 mg/kg) in Ah-responsive C57BL/6 mice, and this effect was accompanied by a decrease in selenium-dependent glutathione peroxidase and an increase in θ glutathione S-transferase. The effect on levels of these Phase II enzymes was not produced by the other congeners in C57BL/6 mice, and did not occur in DBA/2 mice exposed to any of the congeners, indicating the involvement of Ah-receptor mediation. These Phase II enzymes both play protective roles in scavenging intracellularly generated peroxides and the balance of their activities is likely to influence a cell’s ability to withstand damage from peroxides.

#### BODY WEIGHT WASTING, THYMIC ATROPHY, AND PORPHYRIA

In addition to induction of hepatic levels of CYP1A1/1A2/1B1 and induction or repression of some Phase II enzymes, PCB-induced effects that appear to predominately involve Ah-receptor initiated mechanisms include body weight wasting and thymic atrophy from acute exposure (Hori et al. 1997; Safe 1994) and porphyria and porphyria cutanea tardea (Franklin et al. 1997; Smith et al. 1990a, 1990b). For example, single intraperitoneal doses of 5 mg/kg 3,3',4,4',5-pentachlorobiphenyl, a potent inducer of CYP1A1 and a high-affinity Ah-receptor agonist (relative to other PCBs), produced marked body weight wasting in Ah-responsive C57BL/6 mice, but not in DBA/2 mice, which have a low-affinity Ah-receptor (Hori et al. 1997). Showing a link between Ah-receptor responsiveness and development of uroporphyria, female F344 rats had significantly higher hepatic levels of porphyrins and ethoxyresorufin deethylase activity (an indicator of CYP1A1) in response to exposure to 0.005% Aroclor 1254 in the diet for 15 weeks than did male rats (Smith et al. 1990b). A similar gender-specific correlation between porphyrinogenic response and CYP1A induction was observed in iron-loaded F344 rats exposed to single intraperitoneal doses of 63 mg Aroclor 1254/kg (Franklin et al. 1997). In mice of the Ah-responsive C57BL/6 strain, a single dose of iron-dextran (600 mg Fe/kg), followed by feeding of a diet containing 0.01% Aroclor 1254 for up to 12 months, produced markedly increased hepatic levels of porphyrins and liver enlargement, but this response to iron and Aroclor 1254 was not observed in similarly treated DBA/2 mice (Smith et al. 1990a). Exposure to iron-dextran alone caused a moderate porphyria in C57BL/6 mice, but not in DBA/2 mice, lending support to a postulate that there are constitutive genetic differences between these strains that influence porphyria development and do not involve Ah-receptor mediation (Smith et al. 1990a). One mechanistic hypothesis proposes that induction of CYP1A2 by the Ah-receptor-PCB complex leads to generation of a competitive inhibitor of uroporphyrinogen decarboxylase in the liver and subsequent accumulation of porphyrins (Franklin et al. 1997).

#### Ah-RECEPTOR TEF APPROACH TO HEALTH HAZARD ASSESSMENT

A toxicity equivalency factor (TEF) approach to evaluating health hazards from exposure to complex environmental mixtures containing PCBs, CDDs, and chlorinated dibenzofurans (CDFs) has been developed and used to some extent to guide public health decisions because humans are exposed to complex and varying mixtures of these halogenated aromatic hydrocarbons and there are limited toxicological data for these complex mixtures and many of their components (ATSDR 1998; Safe 1990, 1994; van den Berg et al. 1998). PCBs were included in this component-based approach because (1) the spectrum of effects in animals exposed to some PCB mixtures and congeners is similar to the spectrum produced by 2,3,7,8-TCDD (via Ah-receptor initial mediation), and (2) coplanar PCBs display Ah-receptor binding affinities that were related to their potency in producing health effects in rodents such as body weight wasting and inhibition of immunological responses to sheep red blood cells (Safe 1990, 1994). The TEF approach compares the relative potency of individual congeners, based on in vitro or acute in vivo data, with that of 2,3,7,8-TCDD, the best-studied member of this chemical class, so that the TEF for 2,3,7,8-TCDD is 1. The concentration or dose of each active component in a mixture of concern is multiplied by its TEF to arrive at a toxic equivalency (TEQ), and the TEQs are added to give the total toxic equivalency of the mixture which are compared with reference exposure levels for 2,3,7,8-TCDD expected to be without significant risk for producing health hazards. TEFs have recently been recommended by the World Health Organization for 7 CDD, 10 CDF, and 12 PCB congeners (Van den Berg et al. 1998).

Limitations in using the TEF approach for assessing health hazards from PCB-containing environmental media revolve around the inherent assumptions that the components jointly act in an additive manner through a common Ah-receptor initial mechanism and the evidence that Ah-receptor-binding congeners in PCB-containing environmental mixtures are minor components (Hansen 1998; Safe 1998a, 1998b) Several studies have provided evidence of non-additive interactions between specific PCB congeners and between some PCB congeners and 2,3,7,8-TCDD (Safe 1998a, 1998b) and there is evidence, discussed below, that several Ah-receptor-independent mechanisms may make contributions to toxic effects from PCB mixtures.

### PCB Effects Involving Ah-receptor Independent Mechanisms

#### INDUCTION OF HEPATIC CYP2B OXYGENASES

In contrast to the distinct relationships between CYP1A1/1A2 induction, PCB molecular structures, and Ah-receptor initiation of toxic effects, relationships between potency in inducing CYPs 2B1/2B2/3A, PCB structural properties, and toxic effects are less clear (Connor et al. 1995). For example, some PCBs with two ortho chlorines and lateral chlorines induce both types of CYPs and display a very small affinity for the Ah receptor, whereas other di-ortho PCBs with one or two para chlorines predominately induce CYP2B1/2B2/3A and have no measurable affinity for the Ah receptor (Connor et al. 1995; Hansen 1998). Nevertheless, it is clear that PCB induction of phenobarbital-type CYPs is independent of the Ah receptor and that the most potent inducers of CYP have at least two ortho chlorines and one or two para chlorines.

Other PCB-induced effects involving Ah-receptor independent mechanisms include: neurological and neurodevelopmental effects involving changes in brain dopamine levels (Seegal 1996, 1998; Seegal et al. 1989, 1990; Shain et al. 1991), inhibition of dopamine vesicular uptake (Mariussen et al. 1999), and/or changes in brain cell intracellular calcium homeostasis and related signal transduction processes (Kodavanti and Tilson 1997; Tilson and Kodavanti 1997, 1998; Tilson et al. 1998; Wong and Pessah 1996, 1997; Wong et al. 1997); and tissue injury related to activation of neutrophils (Brown and Ganey 1995; Ganey et al. 1993; Tithof et al. 1995).

#### BRAIN DOPAMINE LEVELS AND NEUROLOGICAL EFFECTS

Aroclor 1254 decreased cellular levels of dopamine in cultured pheochromocytoma cells which synthesize, store, release, and metabolize dopamine in a manner similar to the intact mammalian central nervous system (Seegal et al. 1989). Daily oral exposure of adult nonhuman primates (Macaca nemestrina) to Aroclor 1016, a commercial mixture of lightly chlorinated PCB congeners, for 20 weeks, likewise, produced decreased dopamine concentrations in brain regions including the caudate, putamen, substantia nigra, and hypothalamus (Seegal et al. 1990). In these brain regions, only three PCB congeners were detected (2,4,4'-trichlorobiphenyl and 2,2',4,4'- and 2,2',5,5'-tetrachlorobiphenyl), suggesting that nonplanar PCBs, which are poor Ah-receptor agonists, may have been responsible for the effect. Structure-activity studies of 50 PCB congeners in the pheochromocytoma in vitro system found that the most active congeners had two ortho chlorines (e.g., 2,2',4,6-, 2,2',5,5'-, and 2,2',4,5-tetrachlorobiphenyl) and that congeners that were relatively strong Ah-receptor agonists (e.g., 3,3',4,4'-tetrachlorobiphenyl, 3,3',4,4',5-pentachlorobiphenyl) were inactive or had minimal effects on dopamine levels (Shain et al. 1991). However, ortho substitution was not the sole determinant of activity in this system; for example, a congener with four ortho chlorines (2,2',6,6'-tetrachlorobiphenyl) had no effect on dopamine levels in pheochromocytoma cells (Shain et al. 1991). The effect on dopamine levels has been postulated to involve decreased dopamine synthesis via direct or indirect PCB inhibition of tyrosine hydroxylase (Choksi et al. 1997; Seegal 1996) or L-aromatic amino acid decarboxylase (Angus et al. 1997) and/or decreased uptake of dopamine into vesicles (Mariussen et al. 1999). For example, several congeners that were inactive in causing dopamine level changes in pheochromocytoma cells (e.g., 2,2',6,6'- and 3,3',4,4'-tetrachlorobiphenyl) were much less active in inhibiting vesicular uptake of dopamine than other more active congeners (e.g., 2,2',4,6- and 2,2',4,5'-tetrachlorobiphenyl) (Mariussen et al. 1999).

#### DISRUPTION OF CA^+2^ HOMEOSTASIS AND NEUROLOGICAL EFFECTS

Neurological and/or neurodevelopmental effects from exposure to PCBs also have been hypothesized to involve interference with calcium homeostatic mechanisms and intracellular second messenger systems by PCB congeners that are not effective Ah-receptor agonists (see reviews by Kodavanti and Tilson 1997; Tilson and Kodavanti 1998; Tilson et al. 1998). In agreement with structure-activity relationships observed for PCB effects on dopamine levels in pheochromocytoma cells (Shain et al. 1991), 2,2'-dichlorobiphenyl altered intracellular calcium homeostasis in cultured rat cerebellar granule cells (increased free calcium levels and inhibited calcium buffering systems) at non-cytotoxic exposure concentrations (higher concentrations were cytotoxic) (Kodavanti et al. 1993). In contrast, 3,3',4,4',5'-pentachlorobiphenyl, one of the most effective Ah-receptor agonists among tested PCBs (Safe 1994), was not cytotoxic in the tested concentration range and did not alter calcium homeostasis to as great an extent as 2,2'-dichlorobiphenyl (Kodavanti et al. 1993). Using phorbol ester binding in rat cerebellar granule cells as a measure of protein kinase C translocation (which is thought to play key roles in cellular signal transduction in neurons and be regulated by several intracellular factors including intracellular levels of free calcium), commercial mixtures of PCBs (Aroclors 1016, 1254, and 1260) were shown to increase protein kinase C translocation in a concentration-dependent manner with varying potencies (Kodavanti et al. 1995). Aroclors 1016 and 1254 were more potent than Aroclor 1260. Examination of 24 PCB congeners showed that the most potent congeners (e.g., 2,2'-dichlorobiphenyl, 2,2',5,5'-tetrachlorobiphenyl, and 2,2',4,6,6'-pentachlorobiphenyl) had multiple ortho chlorines, whereas congeners without ortho chlorines tended to have either no or lower activities (Kodavanti et al. 1995). Similar results were found in structure-activity studies of 24 PCB congeners and their effects on in vitro Ca^+2^ sequestration by microsomes and mitochondria from freshly isolated rat cerebellar cells (Kodavanti et al. 1996). Structure activity relationships for PCB congeners and protein kinase C translocation in rat cerebellar granule cells and Ca^+2^ sequestration were similar to relationships for PCB congener-induced changes in dopamine levels in pheochromocytoma cells. For example, 2,2',5,5'- and 2,2',4,6-tetrachlorobiphenyl were among the most potent congeners and 2,2',6,6'- and 3,3',4,4'-tetrachlorobiphenyl were inactive in all three systems (Kodavanti et al. 1995, 1996; Shain et al. 1991).

One proposed molecular target for PCB disruption of calcium homeostasis that may be involved in neurological and neurodevelopmental effects is ryanodine-sensitive Ca^+2^ channels. Commercial PCB mixtures with intermediate to high degrees of chlorination (Aroclors 1248, 1254, 1260) enhanced ryanodine binding to calcium release channels in sarcoplasmic reticulum membranes from skeletal or cardiac rabbit muscles, and mixtures with lower (Aroclors 1221, 1232) or higher chlorination (Aroclor 1268) showed little enhancement (Wong and Pessah 1996). Examination of selected pentachlorobiphenyls indicated that ortho substitution favored activity; 2,2',3,5',6–pentachlorobiphenyl induced the greatest enhancement of ryanodine binding, whereas the 3,3',4,4',5-isomer did not enhance binding (Wong and Pessah 1996). The 2,2',4,6,6'-isomer with full substitution at the ortho positions produced less enhancement than the 2,2',3,5',6-isomer, indicating that some degree of rotation about the biphenyl bond may be important for full activity. Results from studies with hippocampal slices from freshly dissected rat brains indicated that perfusion with a triortho congener (2,2',3,5',6-pentachlorobiphenyl) enhanced ryanodine binding and inhibited electrophysiological responses to electrical pulse stimulations, but a mono-ortho congener (2,3',4,4'-tetrachlorobiphenyl) showed no enhancement of ryanodine binding and no inhibition of electrophysiological responses to stimulation (Wong et al. 1997). Offspring of rats exposed to gavage doses of 8 or 32 mg/kg/day 2,2',3,5',6-pentachlorobiphenyl on gestation days 10–16 displayed neurobehavioral changes as adults (depressed open field locomotor activity, faster acquisition on a working memory task, and no changes in a delayed spatial alternation task) and changes in ryanodine binding to calcium channels in specific regions of the brain (e.g., decreased in hippocampus and increased in cerebral cortex) (Schantz et al. 1997). Although it is not understood how these changes in ryanodine binding are specifically related to the observed neurobehavioral changes, the results from this series of studies emphasize the potential importance of Ah-receptor independent mechanisms in PCB-induced neurological and neurodevelopmental effects.

#### NEUTROPHIL FUNCTION AND IMMUNOLOGICAL EFFECTS AND TISSUE DAMAGE

PCB-induced functional changes in neutrophils may be involved in impaired immune defenses against pathogens or enhanced inflammatory responses (e.g., production of reactive oxygen species and cytolytic enzymes) leading to tissue injury. Incubation of quiescent cultured rat peritoneal neutrophils with Aroclor 1242 stimulated neutrophil production of superoxide anion and induced degranulation in a concentration-dependent manner without producing cytotoxicity (Ganey et al. 1993). In neutrophils that were activated for these functions, Aroclor 1242 produced further increases in superoxide anion production, but inhibited the activated degranulation process. Similar effects were observed when neutrophils were incubated with 2,2',4,4'-tetrachlorobiphenyl, a congener that has little affinity for the Ah receptor and induces phenobarbital-type CYPs, but 3,3',4,4'-tetrachlorobiphenyl, an Ah-receptor agonist and inducer of 3-methylcholanthrene-type CYPs, did not affect neutrophil function (Ganey et al. 1993). The effects of 2,2',4,4'-tetrachlorbiphenyl on in vitro production of superoxide anion by neutrophils were inhibited when neutrophils were incubated in the absence of extracellular calcium or in the presence of TMB-8, an antagonist of the intracellular mobilization of calcium (Brown and Ganey 1995). In addition, neutrophil degranulation induced by 2,2',4,4'-tetrachlorobiphenyl was enhanced by coexposure with the calcium ionophore A23187 (Brown and Ganey 1995). A mono-ortho congener, 2,3,4,5-tetrachlorobiphenyl, displayed somewhat different effects on neutrophil functions than those from the 2,2',4,4'-congener; it stimulated degranulation in quiescent and activated neutrophils, but only increased superoxide anion production in activated neutrophils, not in quiescent cells. The results from the neutrophil studies suggest the involvement of an Ah-receptor independent mechanism that involves PCB-induced increases in intracellular calcium or PCB effects on a signal transduction pathway that is dependent on calcium availability (Brown and Ganey 1995).

### PCB Effects Involving Ah-receptor Dependent and Independent Mechanisms

PCB-induced effects that may involve both Ah-receptor dependent and independent mechanisms include liver hypertrophy (Hori et al. 1997); neurodevelopmental effects or reproduction effects involving changes in steroid hormone homeostasis (Arcaro et al. 1999; Connor et al. 1997; Fischer et al. 1998; Gierthy et al. 1997; Li and Hansen 1997; Nesaretnam and Darbre 1997; Nesaretnam et al. 1996; Seegal et al. 1997) and/or thyroid hormone disruption (Brouwer et al. 1998; Hansen 1998; Li and Hansen 1996a, 1996b, 1997); immunological effects (Harper et al. 1993a, 1993b; Silkworth and Grabstein 1982; Stack et al. 1999); and cancer through non-genotoxic mechanisms involving promotion of oncogenic cells (Cogliano 1998; Safe 1994) and/or genotoxic mechanisms (Robertson and Gupta 2000).

#### LIVER HYPERTROPHY

Liver hypertrophy in animals is produced by oral exposure to commercial PCB mixtures and appears to involve both Ah-receptor dependent and independent mechanisms. An illustration of this phenomenon is the observation that single intraperitoneal doses of any one of three PCB congeners varying in affinity for the Ah receptor produced liver hypertrophy in Ah-responsive (C57BL/6) and Ah-non-responsive (DBA/2 mice (Hori et al. 1997). The studied congeners were 3,3',4,4',5-pentachlorobiphenyl, a congener with high Ah-receptor affinity, 3,3',4,4'-tetrachlorobiphenyl, a congener with lesser affinity, and 2,2',5,5'-tetrachlorobiphenyl, a low-affinity Ah-receptor ligand.

#### REPRODUCTIVE EFFECTS

There are several studies examining female reproductive function variables in rats (Brezner et al. 1984; Hany et al. 1999; Linder et al. 1974; Sager and Girard 1994), mice (Welsch 1985), rabbits (Seiler et al. 1994), minks (Aulerich and Ringer 1977; Backlin and Bergman 1995; Kihlstrom et al. 1992), and monkeys (Arnold et al. 1995, 1996; Barsotti et al. 1976) repeatedly exposed orally to commercial PCB mixtures, predominately Aroclor 1254. In general, results from these studies identify minks and monkeys as sensitive species.

In minks, repeated exposure to low doses of Aroclor 1254 or Clophen A-50 (0.4–1.8 mg/kg/day) caused reproductive failure that has been associated with fetal death following embryo implantation (Aulerich and Ringer 1977; Backlin and Bergman 1995; Backlin et al. 1997; Kihlstrom et al. 1992). This effect may predominately involve Ah-receptor mediation, as evidenced by observations that only 1/10 mink exposed to 2.5 ppm Aroclor 1254 in the diet from 1 month prior to breeding through parturition produced offspring, whereas exposure by a similar protocol to 2,2',4,4',5,5'-hexachlorobiphenyl or 2,2',3,3',6,6'-hexachlorobiphenyl at concentrations up to 5 ppm did not influence reproductive performance (Aulerich et al. 1985). In contrast, exposure to dietary concentrations as low as 0.1 ppm 3,3',4,4',5,5'-hexachlorobiphenyl in this study (Auerlich et al. 1985), and 0.05 ppm in another study (Aulerich et al. 1987), caused mortality and prevented the minks for reproducing. Dietary exposure of minks to a fraction of Aroclor 1254, containing only congeners with no ortho-chlorines or a single orthochlorine and representing <20% of the total weight of Aroclor 1254, reduced litter size and fetal survival and increased incidence of interrupted pregnancies to a similar degree as doses of the complete Aroclor 1254 mixture (1.3 mg/kg/day) containing the same amount of these congeners (Kihlstrom et al. 1992). These results suggest the importance of Ah-receptor mediation of PCB-induced reproductive impairment in minks.

Another mink study comparing reproductive effects from intraperitoneal doses of 2,2',4,4',5,5'- and 3,3',4,4',5,5'-hexachlorobiphenyl reinforces the idea that congeners with high Ah-receptor affinity are more potent than congeners with low Ah-receptor affinity, but also provides evidence that Ah-receptor independent mechanisms may be involved (Patnode and Curtis 1994). Administration of single 20-mg/kg doses of the 2,2',4,4',5,5'-isomer (a poor Ah-receptor agonist that has been detected in wild mink tissues at concentrations 50-fold greater than the 3,3',4,4',5,5'-isomer) to pregnant minks on the approximate date of implantation did not affect the number of implantation sites (assayed 14 days after dose administration), but significantly decreased the number of embryos and embryonic weight, crown-to-rump length, and head length. The 3,3',4,4',5,5'-isomer (at lower dose levels of 0.4 or 0.8 mg/kg) also did not affect the number of implantation sites, but produced more severe effects on embryo survival and the weight, crown-to-rump length, and head length of surviving embryos (Patnode and Curtis 1994).

The mechanisms involved in PCB-induced reproductive impairment in minks are unknown, but examination of mid- to late-gestation placentae from minks exposed to Clophen A50 by light and electron microscopy revealed degenerative lesions in maternal (endothelial detachment and thrombosis in maternal vessels) and fetal (trophoblastic disintegration and loss of fetal capillary integrity) tissues (Backlin et al. 1998). Jones et al. (1997) postulated that the mechanisms are likely to be multifactorial given the possibility of direct and/or indirect tissue damaging actions of PCBs and the wide range of reported effects of PCBs on steroid hormone synthesis and functions including PCB regulation of CYP oxygenases that activate or deactivate different endogenous steroid hormones, estrogenic and antiestrogenic effects of PCBs, and PCB regulation of estrogen and progesterone receptor levels (see Battershill 1994; Li and Hansen 1997; Patnode and Curtis 1994).

Impaired ability to conceive and decreased fetal survival have been observed following repeated exposure of female Rhesus monkeys to commercial PCB mixtures. Exposure to dietary levels of 2.5 or 5 ppm Aroclor 1248 (approximately 0.1 or 0.2 mg/kg/day) for 16–19 months (including a 7-month period before breeding with non-exposed males) produced resorptions or abortions in 3/8 and 4/6 impregnated female Rhesus monkeys, compared with 0/12 in a control group (Barsotti et al. 1976). In this study, 12/12, 8/8, and 6/8 females became impregnated in the 0-, 2.5-, and 5-ppm groups, respectively. Another study fed encapsulated Aroclor 1254 at dose levels of 0, 0.005, 0.02, 0.04, or 0.08 mg/kg/day to female Rhesus monkeys for 37 months before breeding with non-exposed males and continued dosing through mating and gestation (Arnold et al. 1995). Incidences of abortions, resorptions, or stillbirths were 2/11, 5/10, 3/4, 2/6, and 4/5 in impregnated monkeys in the control through high-dose groups, respectively; respective incidences for impregnation success were 11/16, 10/16, 4/15, 6/14, and 5/15 (Arnold et al. 1995). Mechanisms for these effects in monkeys are unknown, but microscopic examination of tissues from control and exposed monkeys in the second monkey study found no evidence for an association with endometriosis (Arnold et al. 1996).

The plausibility that PCB effects on reproductive function (and other functions such as neurobehavior and immunological competence) may involve PCB effects on endocrine functions has led to investigations of the estrogenic and anti-estrogenic activities of PCB mixtures and individual congeners, and the effects of PCBs or related halogenated aromatic compounds on steroid hormone metabolism via induction of Phase I or Phase II enzymes. How these PCB effects are specifically related to PCB effects on reproductive function is unknown, but the results of these investigations provide further evidence that reproductive effects from PCB mixtures may not be restricted to Ah-receptor mediation alone and are likely to involve multiple mechanisms that have yet to be elucidated.

The estrogenic and anti-estrogenic activities of some commercial PCB mixtures, PCB congeners, and hydroxylated derivatives of PCB congeners have been assayed by examining uterine variables in immature or ovariectomized female rodents, cell proliferation or gene expression variables in cultured cells including human breast cancer or HeLa cells, and in vitro binding to estrogen receptor preparations (see Andersson et al. 1999; Arcaro et al. 1999; Battershill 1994; Connor et al. 1997; Gierthy et al. 1997; Hansen 1998; Kramer et al. 1997; Krishnan and Safe 1993; Li and Hansen 1997; Moore et al. 1997; Safe 1998a; Safe 1999 for reviews). In general, PCB-induced estrogenic activities have been characterized as weak compared to the endogenous hormone, 17β-estradiol, a wide variability of responses has been observed across types of PCBs and assays indicating the involvement of multiple mechanisms (e.g., direct binding to the estrogen receptor is not the only way that estrogenic or anti-estrogenic physiological effects may be mediated), anti-estrogenic activities have been most strongly associated with PCBs that are Ah receptor agonists, and hydroxylated metabolites of PCBs are postulated to be at least partly responsible for physiological responses to PCBs that may involve changes in estrogen receptor-dependent physiological processes.

Early studies showed that subcutaneous administration of 8 mg of Aroclors 1221, 1232, 1242, or 1248 increased uterine weight and glycogen content in rats, but similar exposure to Aroclors 1254, 1260, 1262, or 1268 did not produce this estrogenic effect (Bitman and Cecil 1970). More recent studies have provided further evidence that PCB mixtures can produce estrogenic responses (albeit weak) and that PCB congeners with multiple ortho chlorines (or their hydroxylated metabolites) may be at least partly responsible for these responses. Intraperitoneal doses of Aroclor 1242 (8 mg/rat on day 20 or 0.08 or 0.32 mg/rat on days 20 and 21) significantly increased uterine wet weight in immature female rats to about 40% of the increase produced by 0.001 mg 17β-estradiol (Jansen et al. 1993). Similar increases in uterine wet weight were produced by exposure to di-ortho congeners or hydroxylated derivatives (0.640 mg 2,2',5,5'-tetrachlorobiphenyl or 0.250 mg 2,4,6–trichloro-4'-hydroxy-biphenyl on days 20 and 21), but not by exposure to a coplanar congener without ortho chlorines (0.160 mg 3,3',4,4'-tetrachlorobiphenyl). In another study, the tetra-ortho congener, 2,2',6,6'-tetrachlorobiphenyl, displayed similarly weak estrogenic responses in an in vitro human breast cancer cell assay and an in vivo immature female rat assay (Arcaro et al. 1999). This congener did not competitively bind in vitro to recombinant human estrogen receptors α and β, but a hydroxylated metabolite, 2,2',6,6'-tetrachloro-4'-hydroxy-biphenyl, competitively bound to estrogen receptor α and produced proliferative responses in the breast cancer assay at concentrations about 10-fold lower than effective concentrations of the parent molecule (Arcaro et al. 1999).

Combined exposure of immature rats to 0.32 mg Aroclor 1242 and 0.001 mg 17β-estradiol produced a response similar to estradiol alone, indicating no obvious anti-estrogenic activity, but combined exposure to 0.001 mg estradiol and 0.160 mg 3,3',4,4'-tetrachlorobiphenyl markedly diminished the estradiol-induced increase in uterine wet weight (Jansen et al. 1993). Anti-estrogenic effects similar to those from 3,3',4,4'-tetrachlorobiphenyl were observed in rodent uterine tissue (Astroff and Safe 1990) and human breast cancer cells (Krishnan and Safe 1993) by other congeners with no or single ortho chlorines (e.g., 3,3',4,4',5-pentachlorobiphenyl, 2',3,3',4,4',5-hexachlorobiphenyl), but commercial PCB mixtures were not anti-estrogenic in the breast cancer cell assay. Whereas the data collected by Krishnan and Safe (1993) suggest that anti-estrogenic activities of PCBs may be related to Ah-receptor binding affinity, antiestrogenic activities of hydroxylated PCB congeners with multiple ortho chlorines have been observed in several assay systems (Connor et al. 1997; Moore et al. 1997; Safe et al. 1998a).

Structure-activity relationships for estrogenic activities of PCB congeners or their metabolites are less clear. Some hydroxylated PCBs (2,4,6-trichloro-4'-hydroxy-biphenyl and 2,3,4,5-tetrachloro-4'-hydroxybiphenyl) have been demonstrated to competitively bind to mouse estrogen receptor preparations and to increase uterine weight and glycogen in immature mice (Korach et al. 1988). In other estrogenic assays, 2,2',4,4',6-tetrachlorobiphenyl, 2,4,4',6-tetrachloro-4-hydroxy-biphenyl, and 2,4,6-trichloro-4'-hydroxybiphenyl were equally effective in stimulating proliferation of human breast cancer cells, but only 2,4,6-trichloro-4'-hydroxy-biphenyl caused significant induction of vitellogenin in cultured brown trout hepatocytes (Andersson et al. 1999). A structure-activity study of eight hydroxylated PCBs in a series of in vivo and in vitro estrogenic assays found that structure activity relationships were complex and differed from one assay to the next (Connor et al. 1997; Safe et al. 1998a). For example, all but one of the compounds displayed competitive binding to rat and mouse cytosolic estrogen receptors (affinities ranged from about 10^−3^ to 10^−5^ of 17β-estradiol’s affinity), but no estrogenic activities (wet weight, peroxidase activity, progesterone receptor level) were produced in the uteri of immature rats and mice exposed to three consecutive daily doses of the individual hydroxylated PCB congeners at levels of 25, 50, or 100 mg/kg. In contrast, four of the hydroxylated congeners produced estrogenic effects in cultured human breast cells and HeLa cells (Connor et al. 1997; Safe et al. 1998a).

Complex effects on male reproductive organs and functions have been observed in animals exposed to commercial PCB mixtures including reduced testes weight in adult male offspring of guinea pigs exposed during gestation to Clophen A50 (Lundkvist 1990), reduced testes weight in adult male offspring of female rats exposed from 50 days prior to mating through birth of offspring to 4 mg/kg/day Aroclor 1254 or a mixture of PCBs reflective of the composition of human milk samples (Hany et al. 1999), reduced fertility (without changes in reproductive organ weights, sperm production, or sperm morphology) in adult male offspring of female rats exposed to doses of 8 mg/kg Aroclor 1254 and higher on lactation days 1, 3, 5, 7, and 9 (Sager et al. 1987, 1991), and elevated testes weight and increased sperm production in adult rats exposed to subcutaneous doses of Aroclor 1242 or 1254 (0.4 to 3.2 mg/day) on postnatal days 0–25 (Cooke et al. 1996). Mechanisms involved in these effects on male reproductive organ development are unknown but have been postulated to involve developmentally specific periods of responsiveness such as long-lasting elevation of testosterone-metabolizing enzymes from in utero exposure leading to reduced testes weight (Hany et al. 1999) and continued depression of thyroid hormone levels during the neonatal period leading to Sertoli cell proliferation and increased testes weight (Cooke et al. 1996). Whether or not PCB estrogenic and anti-estrogenic effects may be involved in any of these effects is unknown, but decreases in adult testis size and sperm production following early developmental exposure to other estrogenic compounds such as 2,3,7,8-TCDD is well documented (Gray et al. 1995).

#### DISRUPTION OF THYROID HORMONE HOMEOSTASIS

Concern that the thyroid hormone system may be important in PCB mechanisms of toxicity stems from mainly two important types of observations (Brouwer et al. 1998; Porterfield and Hendry 1998): (1) extensively corroborated findings in experimental animals that exposure to PCBs in utero and/or during early development (e.g., through breast milk) can deplete levels of circulating thyroid hormone in the fetus or neonate, which may give rise to a hypothyroid state during development (Collins and Capen 1980; Cooke et al. 1996; Corey et al. 1996; Darnerud et al. 1996; Goldey et al. 1995; Juarez de Ku et al. 1994; Li et al. 1998; Morse et al. 1996; Provost et al. 1999; Rice 1999; Schuur et al. 1998a; Seo and Meserve 1995; Zoeller et al. 2000); and (2) the recognition of the importance of thyroid hormones in normal development of the brain, as evident from neurodevelopmental disorders and deficits associated with hypothyroidism (Boyages 2000). The latter are typified by iodine deficiency (e.g., endemic cretinism), which can produce a wide range of neurodevelopmental deficits, including auditory, motor, and intellectual deficits. These outcomes suggest an importance of thyroid hormones in the normal development of the fetal cochlea, basal ganglia, and cerebral cortex, which begin to develop in humans during the second trimester of gestation. This is also the time in which the fetal thyroid gland becomes functional.

Evidence for a potential thyroid hormone involvement in PCB toxicity rests largely on observations made in experimental animals, including rodents and nonhuman primates. Although the studies differ in design, the emerging picture from these studies is that, depending on dose and duration, PCBs can disrupt the production and disposition of thyroid hormones at a variety of levels. The major findings include: (1) histological changes in the thyroid gland indicative of both stimulation of the gland (e.g., similar to that induced by thyroid stimulating hormone [TSH] or a hypothyroid state) and a disruption of the processing of follicular colloid needed for normal production and secretion of thyroid hormone (ATSDR 2000); (2) depression of serum T_4_ and T_3_ levels, which may effectively create a hypothyroid state (ATSDR 2000); (3) increased rates of elimination of T_4_ and T_3_ from serum (Goldey and Crofton 1998); (4) increased activities of T_4_-UDP-GT in liver (Chu et al. 1995; Desauliniers et al. 1997; Morse et al. 1996; Schuur et al. 1998a; Van Birgelen et al. 1995), which is an important metabolic elimination pathway for T_4_ and T_3_; (5) decreased activity of iodothyronine sulfotransferases in liver which are also important in the metabolic elimination of iodothyronines (Schuur et al. 1998a, 1998b, 1999); (6) decreased activity of iodothyronine deiodinases including brain Type-2 deiodinase, which provide the major pathways for the production of the active thyroid hormone, T_3_ (Morse et al. 1996; Schuur et al. 1998a); and (7) decreased binding of T_4_ to transthyretin an important transport protein for both T_4_ and T_3_ (Cheek et al. 1999; Darnerud et al. 1996).

The above observations suggest that PCBs can disrupt the production of thyroid hormones, both in the thyroid and in peripheral tissues, can interfere with their transport to peripheral tissues, and can accelerate the metabolic clearance of thyroid hormones. The most convincing evidence that PCBs can exert toxicity by disrupting the thyroid hormone system derives from two studies in rats. In one study, neurobehavioral deficits in pups that experienced exposures to Aroclor 1254 in utero and during nursing, were significantly attenuated by subcutaneous injections of T_4_ that increased serum T_4_ and T_3_ concentrations that were otherwise depressed in the PCB-exposed animals (Goldey and Crofton 1998). While this study examined relatively high doses of Aroclor 1254 (≥1 mg/kg/day), it nevertheless demonstrated neurodevelopmental effects that are directly relevant to observations made in epidemiological studies and to neurological sequelae of fetal hypothyroidism, including motor disturbances and hearing.

In the second study, increased testes weight and sperm production in rats that were administered Aroclor 1254 on postnatal days 1–25 were attenuated by injections of T_4_ on postnatal days 1–25, which also prevented the depression in serum T_4_ concentrations (Cooke et al. 1996). Here again, although produced by relatively large doses of Aroclor 1254 (≥40 mg/kg/day, subcutaneous), similar effects can be produced by other hypothyroid-inducing agents, including 6-propyl-2-thiouracil (PTU). Furthermore, the effects observed may reflect a disruption of the normal sexual maturation process, which is known to be associated with neonatal hypothyroidism in humans (Longcope 2000).

The effects PCBs on thyroid hormone status appear to involve Ah-receptor mediated actions as well as actions that appear to be independent of the Ah receptor. Depressed levels of serum T_4_ have been observed in rats given oral doses of coplanar PCB congeners (Desauliniers et al. 1997; Van Birgelen et al. 1994) or di-ortho-substituted congeners that have relatively low affinity for the Ah receptor (Ness et al. 1993; Van Birgelen et al. 1992). At least one potential Ah-receptor mediated mechanism for this effect is the induction of UDP-GT, which catalyzes the metabolic elimination of T_4_ to the T_4_-glucuronide conjugate (Desauliniers et al. 1997; Van Birgelen et al. 1995). However, the UDP-GT mechanism does not appear to be important in the depression of T_4_ levels produced by non-coplanar PCBs. Li and Hansen (1996a) observed depressed serum T_4_ levels in rats administered a PCB mixture extracted from soil. Treatment of the mixture with activated charcoal greatly reduced the content of co-planar PCBs in the mixture, substantially decreased the potency of the mixture for inducing UDG-GT and ethoxyresourufin-O-deethylase (EROD), but had little effect on the potency for depressing T_4_ levels. This suggests that an Ah-independent mechanism may exist that is not related to UDP-GT induction.

PCBs, including poly-ortho-substituted PCBs, which have a very low affinity for the Ah receptor, inhibit the binding of T_4_ to transthyretin, an important transport protein for both T_4_ and T_3_ (Chauhan et al. 2000; Cheek et al. 1999; Darnerud et al. 1996). Inhibition of binding of thyroid hormones to transthryetin could alter hormone delivery to target tissues, including the brain, and could also result in depressed levels of serum total TT_4_ or TT_3_ (Brouwer et al. 1998).

#### IMMUNOLOGICAL EFFECTS

Studies with inbred mice strains differing in Ah-receptor responsiveness indicate that immunosuppression from PCB mixtures involves Ah-receptor mediation (e.g., Silkworth and Grabstein 1982; Harper et al. 1993a), but there is evidence that other mechanisms also may contribute to PCB-induced immunological effects (Harper et al. 1993a, 1993b; Stack et al. 1999). Illustrating the importance of Ah-receptor mediation for some PCB congeners, Ah-responsive C57BL/6 mice given single intraperitoneal doses of 100 mg/kg 3,3',4,4'-tetrachlorobiphenyl showed marked decreases in the number of splenic plaque-forming cells (PFCs) formed in response to immunization with sheep red blood cells (SRBCs, which are T-cell dependent antigens) compared with similarly treated Ah-non-responsive DBA/2 mice (Silkworth and Grabstein 1982). In addition, median effective doses (ED_50_) values for 2,3,7,8-TCDD, three chlorinated dibenzofurans, and two PCBs without ortho substitution (3,3',4,4',5-pentachlorobiphenyl and 3,3',4,4',5,5'-hexachlorobiphenyl) in this immunotoxicity assay were lower in C57BL/6 mice than in DBA/2 mice, and the order of immunotoxic potency of these six compounds was the same as that for potency in inducing CYP1A1 (Harper et al. 1993a). In another study, a series of four hexachlorinated biphenyls with differing chlorine substitution patterns displayed varying ED_50_ values in the same immunotoxicity assay as follows: 2, >1,000, 120, and >1,000 μmole/kg for a monoortho (2,3,3',4,4',5'-), a diortho- (2,2',4,4',5,5'-), a triortho- (2,2', 4,4', 5',6-), and a tetraortho-isomer (2,2',4,4',6,6'-), respectively (Harper et al. 1993b). Harper et al. (1993b) concluded that immunotoxic potency decreases (i.e., ED_50_s increase) with increasing ortho-chlorine substitution of PCBs, but, as shown above, the decrease was not monotonic with increasing degree of chlorination. Furthermore, this relationship did not apply to more highly chlorinated PCBs with three or four ortho chlorines that are inactive as Ah-receptor agonists and only minimally induce CYP1A1 (Harper et al. 1993b). Three nonachlorobiphenyls (2,2,’3,3',4,4',5,5',6-, 2,2,’,3,3',4,4',5,6,6'-, and 2,2',3,3',4,5,5',6,6'-nonachlorobiphenyl) and decachlorobiphenyl displayed ED_50_s for inhibition of the splenic PFC response to SRBC in C57BL/6 mice that were less than those for hexachlorobiphenyl isomers with multiple ortho chlorines reported above: 15, 7, 17, and 35 μmole/kg, respectively. These results are consistent with the hypothesis that some PCBs induce immunotoxicity via Ah-receptor independent mechanisms. In an in vitro assay of cell proliferation in response to lipopolysaccharide (a T-cell independent antigen), Aroclors 1221, 1242, 1254, or 1260 inhibited the proliferative response similarly in splenocytes from either C57BL/6 or DBA/2 mice (Stack et al. 1999). Two non-ortho and two mono-ortho PCBs that have been demonstrated to be effective Ah-receptor agonists and CYP1A1 inducers did not inhibit the in vitro proliferative response to lipopolysaccharide, but two di-ortho congeners (2,2',3,4,4',5- and 2,2',4,4',5,5'-hexachlorobiphenyl) significantly inhibited the response. These in vitro results provide supporting evidence for the existence of mechanisms of PCB immunotoxic actions that are independent of the Ah receptor.

#### CANCER

Lifetime oral exposure to any one of four commercial PCB mixtures (Aroclors 1016, 1242, 1254, and 1260) has been demonstrated to produce liver tumors in female rats; Aroclor 1260 also induced liver tumors in male rats (Mayes et al. 1998). Mixtures with high chlorination content (e.g., Aroclor 1254) were generally more potent than mixtures with low chlorine content (e.g., Aroclor 1016) (Mayes et al. 1998). Tumor promotion by commercial PCB mixtures following initiation by a variety of chemical agents also has been investigated in a number of animal systems including rat liver, rat kidney, mouse skin, and newborn mouse liver and lung (see Silberhorn et al. 1990 for review). The tumor promoting effect of extended exposure to PCB mixtures was demonstrated principally in the liver of rats; there is some evidence that PCB mixtures also can promote tumors in mouse lung and mouse skin, but not in rat kidneys. The mechanism of PCB-induced cancer is poorly understood, but there is evidence to suggest that both Ah-receptor dependent and independent mechanisms may be involved.

PCB promotion of tumors does not appear to be solely an Ah-receptor mediated process, since individual congeners that are not Ah-receptor agonists have tumor promotion capabilities in animal systems. For example, 2,2',5,5'-tetrachlorobiphenyl, 2,2',4,4'-tetrachlorobiphenyl, and 2,2',4,4',5,5'-hexachlorobiphenyl were shown to promote liver tumors in female Sprague-Dawley rats (Hemming et al. 1993; Preston et al. 1985). In addition, 2,2',5,5'-tetrachlorobiphenyl, 2,2',3,3',4,4'-hexachlorobiphenyl, and 2,2',4,4',5,5'-hexachlorobiphenyl were potent inhibitors of in vitro gap junctional cellular communication, an assay that is indicative of tumor promotion capacity (Bager et al. 1997; De Haan et al. 1996). A general working mechanistic hypothesis for PCB promotion of liver tumors involves indirect stimulation of cell proliferation following cell or tissue injury by reactive metabolites of PCBs (Silberhorn et al. 1990). Alternatively, the cell injury could be caused by increased intracellular concentrations of other reactive species (e.g., superoxide anion or other reactive oxygen species) caused by an overall imbalance from PCB-induced perturbations of cellular biochemical processes, including induction of CYP oxygenases and glutathione S-transferases, repression of selenium-dependent glutathione peroxidases, and/or disruption of calcium homeostatic processes and signal transduction pathways (Silberhorn et al. 1990).

PCB mixtures have not shown consistent tumor initiating activity in animal initiation-promotion protocols (Silberhorn et al. 1990), but demonstration that chronic oral exposure to commercial PCB mixtures induced liver tumors in female rats (Mayes et al. 1998) suggests that PCBs may have both tumor initiating and promoting activities. Although PCB mixtures generally have been found to be inactive as mutagens in Salmonella typhimurium strains and in several other tests of genotoxicity that may be predictive of tumor initiation capability (see Silberhorn et al. 1990 for review), in vitro studies with rat microsomes have indicated that metabolism of lower chlorinated PCBs (e.g., 4-chlorobiphenyl, 3,4-dichlorobiphenyl, and 3,4,5-trichlorobiphenyl) can lead to covalently modified macromolecules including proteins and DNA (see Robertson and Gupta 2000 for review). Studies demonstrating the Ah-receptor dependence or independence of this potential genotoxic effect from PCBs were not located. The available data indicate that PCBs are not potent genotoxicants, but the possible involvement of genotoxic mechanisms (involving covalent modification of proteins and/or DNA) in the development of PCB-induced cancer is not without some experimental support.

The relative contribution that Ah-receptor dependent and independent mechanisms may make to carcinogenic responses to PCB mixtures is unknown. Safe (1994) compared carcinogenic responses of female rats to 2,3,7,8-TCDD in the diet with responses of female rats of the same strain to Aroclor 1260 in the diet using the TEF approach. TCDD at a TEQ feed concentration of 2,100-ppt induced hepatic adenocarcinomas in 11/50 (22%) rats, whereas a TEQ of only 1,040 ppt from Aroclor 1260 induced adenocarcinomas in 24/47 (51%) rats. For this situation, the TEF approach markedly underestimated the carcinogenic response to Aroclor 1260. A possible explanation is that PCB congeners that are not Ah-receptor agonists and are abundant in Aroclor 1260 make significant contributions to the mixture’s carcinogenicity. Although this comparison suggests that the TEF approach may underestimate cancer responses to complex PCB mixtures, another study of the tumor promotion activity of a simpler mixture of two CDDs, one CDF, and three PCBs in female rats found that the TEF approach overestimated the observed response by a factor of about 2 (van der Plas et al. 1999). The mixture contained 2,3,7,8-TCDD, 1,2,3,7,8-pentachlorodibenzo-p-dioxin, 2,3,4,7,8-pentachlorodibenzofuran, 3,3',4,4',5- and 2,3',4,4',4-pentachlorobiphenyl, and 2,3,3',4,4',5-hexachlorobiphenyl at relative levels found in Baltic Sea herring. The rats were initiated with an injection of diethylnitrosoamine, 24 hours after a partial hepatectomy and were administered weekly subcutaneous injections of the mixture for 20 weeks starting 6 weeks after initiation. The volume and volume fraction of glutathione S-transferase-positive altered hepatic foci were taken as indicators of tumor promotion activity in this study (van der Plas et al. 1999). Although the composition of this mixture reflected relative concentrations and accounted for >90% of total TEQs in Baltic Sea herring, it did not contain PCBs with multiple ortho chlorines which comprise the predominant bulk of PCB weight in most commercial and environmental mixtures. For example, non-, mono-, and di-ortho congeners accounted for <1, 18, and 82% of PCB weight per gram of fat in human milk samples from Italy (Larsen et al. 1994). Another group of rats was similarly treated with the same synthetic mixture plus a di-ortho PCB congener (2,2',4,4',5,5'-hexachlorobiphenyl), which is one of the predominant PCB congeners in environmental mixtures and has minimal Ah-receptor agonist activity (van der Plas et al. 1999). Mean foci volume and foci volume fraction were increased in rats treated with the supplemented mixture compared with the mixture without the di-ortho congener, but the observed responses were still less than that predicted by the TEF approach. Better understanding of the relative contributions of Ah-receptor dependent and independent mechanisms to the carcinogenicity of PCB mixtures awaits further research.

## E.4 Health Guidelines

ATSDR (2000) derived an intermediate oral MRL for PCB mixtures of 0.03 μg/kg/day based on a LOAEL of 0.0075 mg/kg/day for neurobehavioral alterations in infant monkeys that were exposed to a PCB congener mixture representing 80% of the congeners typically found in human breast milk (Rice 1997, 1998, 1999; Rice and Hayward 1997, 1999). The infant monkeys were given oral doses of 0 or 0.0075 mg/kg/day from birth to 20 weeks of age. The dose level was selected to be equivalent to an approximate daily intake of a nursing human infant whose mother’s milk contains 50 ppb PCBs. Treated monkeys showed decreases and variable increases in response latencies across three tasks of nonspatial discrimination reversal, retarded acquisition of a delayed alternation task, increased errors at short delay task responses, and alterations in fixed-interval and fixed-ratio performance tasks. The findings were interpreted to suggest that postnatal PCB exposure resulted in impaired learning, impaired perserverative behavior, and/or inability to inhibit inappropriate responding. To derive the MRL, the LOAEL was divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

ATSDR (2000) derived an chronic oral MRL for PCB mixtures of 0.02 μg/kg/day based on a LOAEL of 0.005 mg/kg/day for decreased antibody response to sheep red blood cells in Rhesus monkeys exposed to self-ingested capsules of Aroclor 1254 in a glycerol/corn oil mixture (Tryphonas et al. 1989, 1991). The LOAEL was divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

Because consensus has emerged on the inappropriateness of assessing environmental PCBs as if they were Aroclors, EPA has developed an approach for assessing cancer risk from environmental PCBs by considering both toxicity and environmental processes (Cogliano 1998; EPA 1996; IRIS 2000). This approach uses animal studies of commercial PCB mixtures to develop a range of human cancer potency estimates and then considers the effect of environmental processes to determine appropriate values for representative classes of environmental mixtures. Guidance is provided for assessing cancer risks from different exposure pathways, less-than-lifetime and early-life exposures, and mixtures containing dioxin-like constituents.

## E.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to PCB mixtures were derived for endpoints affected by PCBs and one or more of the other chemicals in strontium-cobalt-cesium-trichloroethylene-PCB mixture that is the subject of this Interaction Profile. The relevant endpoints for PCBs in this mixture include hematological, developmental, neurologic, and hepatic endpoints. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (2000), and in particular, the oral LSE table.

### Hepatic Effects

Several studies of groups of humans exposed to PCBs have reported associations between exposure and changes in indices of hepatic damage (e.g., increased serum levels of aspartate aminotransferase), but limitations in study design such as lack of appropriate controls or adjustment of potential confounding variables preclude establishing a causal relationship from the human data (ATSDR 2000). In contrast, studies of orally exposed animals have reported a broad spectrum of PCB-induced hepatic effects including hepatic enzyme induction, liver enlargement, hepatic porphyria, and histopathologic changes in liver tissue ranging from hepatocellular hypertrophy and vacuolization to fatty degeneration, hepatocellular necrosis, bile duct hyperplasia, and liver tumors (ATSDR 2000). The lowest exposure levels associated with liver changes in available animal studies are 0.04 mg/kg/day (no NOAEL was identified) for decreased serum cholesterol in Rhesus monkeys exposed to Aroclor 1254 for 37 months (Arnold et al. 1993a, 1993b), 0.08 mg/kg/day (with a NOAEL of 0.04 mg/kg/day) for increased relative liver weight in Rhesus monkeys exposed to Aroclor 1254 for 72 months (Arnold et al. 1997), 0.2 mg/kg/day (no NOAEL was identified) for hepatocyte necrosis and biliary tract hypertrophy in Rhesus monkeys exposed to Aroclor 1254 for 12 or 28 months (Tryphonas et al. 1986a, 1986b), and 1 mg/kg/day (no NOAEL was identified) for hepatocellular hypertrophy and increased levels of serum enzymes in male rats exposed to Aroclor 1254 or 1260 for 24 months (Mayes et al. 1998). Applying an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from monkeys to humans, and 10 for human variability) to the LOAEL of 0.04 mg/kg/day for decreased serum cholesterol in Rhesus monkeys (Arnold et al. 1993a, 1993b) yields a TTD_HEPATIC_ of 0.1 μg/kg/day for PCB mixtures.

### Neurological Effects

Subtle neurobehavioral changes have been observed in studies of children of mothers consuming large amounts of Great Lakes fish contaminated with PCBs and other biopersistent pollutants (ATSDR 2000). Deficits in measures of neurological development have been associated with increasing indices of PCB exposure, but precise and accurate adjustment for possible confounding variables has not always been possible in these studies. Studies in animals support the human data. Neurobehavioral changes have been observed in rats and monkeys following pre- and/or postnatal exposure to commercial Aroclor mixtures, experimental mixtures of PCBs similar to those found in human breast milk, single PCB congeners, and contaminated fish from the U.S. Great Lakes (ATSDR 2000). As described in Section E.4 above, ATSDR (2000) derived the intermediate oral MRL of 0.03 μg/kg/day for PCB mixtures based on a LOAEL of 0.0075 mg/kg/day (no NOAEL was identified) for neurobehavioral changes in infant monkeys that were orally exposed from birth to 20 weeks of age to a synthetic mixture of PCBs representing 80% of the PCB congeners found in samples of human breast milk and an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolating from monkeys to humans, and 10 for human variability). The intermediate-duration oral MRL is only slightly above the chronic oral MRL of 0.02 μg/kg/day (based on immunological effects in adult monkeys), and is expected to provide protection against possible neurological and neurodevelopmental effects from chronic exposure.

### Developmental Effects

The development of the neurological system appears to be a target of critical public health concern associated with pre- and/or post-natal exposure to PCB mixtures (ATSDR 2000). Subtle neurobehavioral effects suggesting impaired learning or perserverative behavior have been observed in monkeys exposed from birth to 20 weeks to oral doses as low as 0.0075 mg/kg/day (Rice 1997, 1998, 1999; Rice and Hayward 1997, 1999). This dose was estimated to correspond to PCB levels in human breast milk of 50 ppb. As discussed in Section E.4 above, these findings serve as the basis of the intermediate oral MRL of 0.03 μg/kg/day. This value is only slightly above the chronic oral MRL of 0.02 μg/kg/day based on impaired immune response in adult monkeys and is expected to be protective of neurological neurodevelopmental effects from chronic oral exposure to PCBs.

### Hematological Effects

A number of studies have examined the effects of exposure to PCB mixtures on hematological endpoints (see ATSDR 2000). The study of Arnold et al. (1997), which identified a NOAEL of 0.08 mg/kg/day for hematological effects in female Rhesus monkeys exposed daily to Aroclor 1254 for 72 months, was utilized as the basis of TTD derivation. Using this NOAEL and an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for intrahuman variability) to derive a TTD of 8×10^−4^ mg/kg/day (0.8 μg/kg/day).

### Immunological Effects

ATSDR (2000) derived an chronic oral MRL for PCB mixtures of 0.02 μg/kg/day based on a LOAEL of 0.005 mg/kg/day for decreased antibody response to sheep red blood cells in Rhesus monkeys exposed to self-ingested capsules of Aroclor 1254 in a glycerol/corn oil mixture (Tryphonas et al. 1989, 1991). The LOAEL was divided by an uncertainty factor of 300 (10 for use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability).

### Reproductive Effects

Available studies of the reproductive effects have been inconclusive in their conclusions. Mayes et al. (1998) reported no effects on reproductive endpoints in Sprague-Dawley rats exposed for 24 months to Aroclor 1016, 1242, 1254, or 1260 in the concentration range of 4–11 mg/kg/day in the drinking water. However, Allen and Norback (1976) reported that Rhesus monkeys exposed to 0.1 mg/kg/day of Aroclor 1248 in the food for 17 months showed a decrease in spermatogenesis and libido. Arnold et al. (1995) identified a NOAEL of 0.005 mg/kg/day (5 μg/kg/day) and LOAEL of 0.020 mg/kg/day (20 μg/kg/day) for decreased conception rate in female Rhesus monkeys. To the NOAEL of 5 μg/kg/day established in this study, an uncertainty factor of 100 (10 for animal to human extrapolation and 10 for human variability) was applied to give a TTD_REPRO_ of 0.05 μg/kg/day (5×10^−5^ mg/kg/day).

### Summary (TTDs for PCBs)

TTD_HEMATO_ = 0.8 μg/kg/day (8×10^−4^ mg/kg/day)

Chronic oral MRL (based on immunological effects) = 0.02 μg/kg/day (2×10−5 mg/kg/day)

TTD_REPRO_ = 0.05 μg/kg/day (5×10^−5^ mg/kg/day)

Intermediate oral MRL (based on neurodevelopmental effects) = 0.03 μg/kg/day (3×10−5 mg/kg/day)

TTD_HEPATIC_ = 0.1 μg/kg/day (1×10^−4^ mg/kg/day)

## E.6 References

Allen JR, Norback DH. 1976. Pathobiological responses of primates to polychlorinated biphenyl exposure. In: Proceedings of the National Conference on Polychlorinated Biphenyls, EPA 560/6–75-004, 43–49. (As cited in ATSDR 2000.)
Andersson PL, Blom A, Johannisson A, 1999. Assessment of PCBs and hydroxylated PCBs as potential xenoestrogens: In vitro studies based on MCF-7 cell proliferation and induction of vitellogenin in primary culture of rainbow trout hepatocytes. Arch Environ Contam Toxicol 37:145–150. (As cited in ATSDR 2000.)10398763
Angus WGR, Mousa MA, Vargas VM, 1997. Inhibition of L-aromatic amino acid decarboxylase by polychlorinated biphenyls. Neurotoxicology 18:857–868. (As cited in ATSDR 2000.)9339832
Arcaro KF, Yi L, Seegal RF, 1999. 2,2',6,6'-Tetrachlorobiphenyl is estrogenic in vitro and in vivo. J Cell Biochem 72:94–102. (As cited in ATSDR 2000.)10025670
Arnold DL, Bryce F, Karpinski K, 1993a. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (Macaca mulatta) monkeys. Part 1B. Prebreeding phase: Clinical and analytical laboratory findings. Food Chem Toxicol 31(11):811–824. (As cited in ATSDR 2000.)8258410
Arnold DL, Bryce F, McGuire PF, 1995. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (Macaca mulatta) monkeys. Part 2. Reproduction and infant findings. Food Chem Toxicol 33:457–474. (As cited in ATSDR 2000.)7797173
Arnold DL, Bryce F, Stapley R, 1993b. Toxicological consequences of Aroclor 1254 ingestion by female Rhesus (Macaca mulatta) monkeys. Part 1A. Prebreeding phase: Clinical health findings. Food Chem Toxicol 31(11):799–810. (As cited in ATSDR 2000.)8258409
Arnold DL, Nera EA, Stapley R, 1996. Prevalence of endometriosis in Rhesus (Macaca mulatta) monkeys ingesting PCB (Aroclor 1254): Review and evaluation. Fundam Appl Toxicol 31(1):42–55. (As cited in ATSDR 2000.)8998952
Arnold DL, Nera EA, Stapley R, 1997. Toxicological consequences of Aroclor 1254 ingestion by female rhesus (Macaca mulatta) monkeys and their nursing infants. Part 3: Post-reproduction and pathological findings. Food Chem Toxicol 35(12):1191–1207. (As cited in ATSDR 2000.)9449225
Astroff B, Safe S. 1990. 2,3,7,8-Tetrachlorodibenzo-p-dioxin as an antiestrogen: Effect on rat uterine peroxidase activity. Biochem Pharmacol 39:485–488. (As cited in ATSDR 2000.)2154986
ATSDR. 1998. Toxicological profile for chlorinated dibenzo-p-dioxins. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service. Agency for Toxic Substances and Disease Registry.
ATSDR. 2000. Toxicological profile for polychlorinated biphenyls (PCBs). Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001a. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
Aulerich RJ, Ringer RK. 1977. Current status of PCB toxicity to mink, and effect on their reproduction. Arch Environ Contam Toxicol 6:279–292. (As cited in ATSDR 2000.)409355
Aulerich RJ, Bursian SJ, Breslin WJ, 1985. Toxicological manifestations of 2,4,5, 2',4',5'-, 2,3,6,2',3',6'-, and 3,4,5,3',4',5'-hexachlorobiphenyl and Aroclor 1254 in mink. J Toxicol Environ Health 15:63–79. (As cited in ATSDR 2000.)
Aulerich RJ, Bursian SJ, Evans MG, 1987. Toxicity of 3,4,5,3',4',5'-hexachlorobiphenyl to mink. Arch Environ Contam Toxicol 16:53–60. (As cited in ATSDR 2000.)3101620
Backlin BM, Bergman A. 1995. Histopathology of postpartum placental sites in mink (Mustela vison) exposed to polychlorinated biphenyls or fractions thereof. APMIS 103(12):843–54. (As cited in ATSDR 2000.)8562024
Backlin BM, Madej A, Forsberg M. 1997. Histology of ovaries and uteri and levels of plasma progesterone, oestradiol-17beta and oestrone sulphate during the implantation period in mated and gonadotrophin-releasing hormone-treated mink (Mustela vison) exposed to polychlorinated biphenyls. J Appl Toxicol 17(5):297–306. (As cited in ATSDR 2000.)9339742
Backlin BM, Persson E, Jones CJ, 1998. Polychlorinated biphenyl (PCB) exposure produces placental vascular and trophoblastic lesions in the mink (Mustela vison): a light and electron microscopic study. APMIS 106(8):785–99. (As cited in ATSDR 2000.)9744765
Bager Y, Kato Y, Kenne K, 1997. The ability to alter the gap junction protein expression outside GST-P positive foci in liver of rats was associated to the tumour promotion potency of different polychlorinated biphenyls. Chem Biol Interact 103(3):199–212. (As cited in ATSDR 2000.)9134010
Barsotti DA, Marlar RJ, Allen JR. 1976. Reproductive dysfunction in Rhesus monkeys exposed to low levels of polychlorinated biphenyls (Aroclor 1248). Food Cosmet Toxicol 14:99–103. (As cited in ATSDR 2000.)817997
Battershill JM. 1994. Review of the safety assessment of polychlorinated biphenyls (PCBs) with particular reference to reproductive toxicity. Hum Exp Toxicol 13:581–597. (As cited in ATSDR 2000.)7986570
Bergman A, Athanasiadou M, Bergek S, 1992. PCB and PCB methyl sulfones in mink treated with PCB and various PCB fractions. Ambio 21(8):570–576. (As cited in ATSDR 2000.)
Bitman J, Cecil HC. 1970. Estrogenic activity of DDT analogs and polychlorinated biphenyls. J Agric Food Chem 18:1108–1112. (As cited in ATSDR 2000.)5483049
Boyages SC. 2000. The neuromuscular system and brain in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner & Ingbar’s the thyroid: A fundamental and clinical text. Eighth edition. Philadelphia, PA: Lippincott Williams & Wilkins, 804–810. (As cited in ATSDR 2000.)
Brandt I, Bergman A. 1987. PCB methyl sulphones and related compounds: Identification of target cells and tissues in different species. Chemosphere 8/9:1671–1676. (As cited in ATSDR 2000.)
Brezner E, Terkel J, Perry AS. 1984. The effect of Aroclor 1254 (PCB) on the physiology of reproduction in the female rat-I. Comp Biochem Physiol 77:65–70. (As cited in ATSDR 2000.)
Brouwer A, Morse DC, Lans MC, 1998. Interactions of persistent environmental organohalogens with the thyroid hormone system: Mechanisms and possible consequences for animal and human health. Toxicol Ind Health 14(1–2):59–84. (As cited in ATSDR 2000.)9460170
Brown AP, Ganey PE. 1995. Neutrophil degranulation and superoxide production induced by polychlorinated biphenyls are calcium dependent. Toxicol Appl Pharmacol 13:198–205. (As cited in ATSDR 2000.)
Chauhan KR, Kodavanti PRS, McKinney JD. 2000. Assessing the role of ortho-substitution on polychlorinated biphenyl binding to transthyretin, a thyroxine transport protein. Toxicol Appl Pharmacol 162:10–21. (As cited in ATSDR 2000.)10631123
Cheek AO, Kow K, Chen J, 1999. Potential mechanisms of thyroid disruption in humans: Interaction of organochlorine compounds with thyroid receptor, transthyretin, and thyroid-binding globulin. Environ Health Perspect 107(4):273–278. (As cited in ATSDR 2000.)
Choksi NY, Kodavanti PRS, Tilson HA, 1997. Effects of polychlorinated biphenyls (PCBs) on brain tyrosine hydroxylase activity and dopamine synthesis in rats. Fundam Appl Toxicol 39:76–80. (As cited in ATSDR 2000.)9325030
Chu I, Villeneuve DC, Yagminas A, 1995. Toxicity of PCB 77 (3,3',4,4'-tetrachlorobiphenyl) and PCB 118 (2,3',4,4',5-pentachlorobiphenyl) in the rat following subchronic dietary exposure. Fundam Appl Toxicol 26:282–292. (As cited in ATSDR 2000.)7589917
Cogliano VJ. 1998. Assessing the cancer risk from environmental PCBs. Environ Health Perspect 106(6):317–323. (As cited in ATSDR 2000.)9618347
Collins WT, Capen CC. 1980. Fine structural lesions and hormonal alterations in thyroid glands of perinatal rats exposed in utero and by the milk to polychlorinated biphenyls. Am J Pathol 99:125–142. (As cited in ATSDR 2000.)6767410
Connor K, Ramamoorthy K, Moore M, 1997. Hydroxylated polychlorinated biphenyls (PCBs) as estrogens and antiestrogens: Structure-activity relationships. Toxicol Appl Pharmacol 145:111–123. (As cited in ATSDR 2000.)9221830
Connor K, Safe S, Jefcoate CR, 1995. Structure-dependent induction of CYP2B by polychlorinated biphenyl congeners in female Sprague-Dawley rats. Biochem Pharmacol 50(11):1913– 1920. (As cited in ATSDR 2000.)8615872
Cooke PS, Zhao Y-D, Hansen LG. 1996. Neonatal polychlorinated biphenyl treatment increases adult testis size and sperm production in the rat. Toxicol Appl Pharmacol 136:112–117. (As cited in ATSDR 2000.)8560463
Corey DA, Juarez de Ku LM, Bingman VP, 1996. Effects of exposure to polychlorinated biphenyl (PCB) from conception on growth, and development of endocrine, neurochemical, and cognitive measures in 60 day old rats. Growth Dev Ageing 60:131–143. (As cited in ATSDR 2000.)
Darnerud PO, Morse D, Klasson-Wehler E, 1996. Binding of a 3,3', 4,4'-tetrachlorobiphenyl (CB-77) metabolite to fetal transthyretin and effects on fetal thyroid hormone levels in mice. Toxicology 106(1–3):105–114. (As cited in ATSDR 2000.)8571380
De Haan LHJ, Halfwerk S, Hovens SEL, 1996. Inhibition of intercellular communication and induction of ethoxyresorufin-O-deethylase activity by polychlorobiphenyls, -dibenzo-p-dioxins and -dibenzofurans in mouse hepa1c1c7 cells. Environ Toxicol Pharmacol 1:27–37. (As cited in ATSDR 2000.)21781660
Desaulniers D, Poon R, Phan W, 1997. Reproductive and thyroid hormone levels in rats following 90-day dietary exposure to PCB 28 (2,4,4'-trichlorobiphenyl) or PCB 77 (3,3'4,4'-tetrachlorobiphenyl). Toxicol Ind Health 13(5):627–638. (As cited in ATSDR 2000.)9284533
EPA. 1996. PCBs: Cancer dose-response assessment and application to environmental mixtures. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, National Center for Enviromental Assessment. EPA/600/P-96/001F. (As cited in ATSDR 2000.)
Panel Expert. 1994. Interpretive review of the potential adverse effects of chlorinated organic chemicals on human health and the environment: Chapter 5: Polychlorinated biphenyls. Regul Toxicol Pharmacol 20(1):S187–S307. (As cited in ATSDR 2000.)
Fischer LJ, Seegal RF, Ganey PE, 1998. Symposium overview: Toxicity of non-coplanar PCBs. Toxicol Sci 41:49–61. (As cited in ATSDR 2000.)9520341
Franklin MR, Phillips JD, Kushner JP. 1997. Cytochrome P450 induction, uroporphyrinogen decarboxylase depression, porphyin accumulation and excretion, and gender influence in a 3-week rat model of porphyria cutanea tarda. Toxicol Appl Pharmacol 147:289–299. (As cited in ATSDR 2000.)9439724
Ganey PE, Sirosis JE, Denison M, 1993. Neutrophil function after exposure to polychlorinated biphenyls in vitro. Environ Health Perspect 101:430–434. (As cited in ATSDR 2000.)8119254
Gierthy JF, Acaro KF, Floyd M. 1997. Assessment of PCB estrogenicity in a human breast cancer cell line. Chemosphere 34(5–7):1495–1505. (As cited in ATSDR 2000.)9134682
Gladen BC, Rogan WJ. 1991. Effects of perinatal polychlorinated biphenyls and dichlorobiphenyl dichloroethene on later development. J Pediatr 119:58–63. (As cited in ATSDR 2000.)1906100
Gladen BC, Rogan WJ, Hardy P, 1988. Development after exposure to polychlorinated biphenyls and dichlorodiphenyl dichloroethene transplacentally and through human milk. J Pediatr 113:991–995. (As cited in ATSDR 2000.)3142988
Goldey ES, Crofton KM. 1998. Thyroxine replacement attentuates hypothyroxinemia, hearing loss, and motor deficits following developmental exposure to Aroclor 1254 in rats. Toxicol Sci 45:94–105. (As cited in ATSDR 2000.)9848116
Goldey ES, Kehn LS, Lau C, 1995. Development exposure to polychlorinated biphenyls (Aroclor 1254) reduces circulating thyroid hormone concentrations and causes hearing deficits in rats. Toxicol Appl Pharmacol 135:77–88. (As cited in ATSDR 2000.)7482542
Gray LE, Kelce WR, Monosson E, 1995. Exposure to TCDD during development permanently alters reproductive function in male Long Evans rats and hamsters: Reduced ejaculated and epididymal sperm numbers and sex accessory gland weights in offspring with normal androgenic status. Toxicol Appl Pharmacol 131:108–118. (As cited in ATSDR 2000.)7878665
Hansen LG. 1998. Stepping backward to improve assessment of PCB congener toxicities. Environ Health Perspect Suppl 106(1):171–189. (As cited in ATSDR 2000.)
Hansen H, DeRosa CT, Pohl H, 1998. Public health challenges posed by chemical mixtures. Environ Health Perspect 106(Suppl. 6):1271–1280. (As cited in ATSDR 2000.)9860881
Hany J, Lilienthal H, Sarasin A, 1999. Developmental exposure of rats to a reconstituted PCB mixture or Aroclor 1254: Effects on organ weights, aromatase activity, sex hormone levels, and sweet preference behavior. Toxicol Appl Pharmacol 158:231–243. (As cited in ATSDR 2000.)10438656
Harper N, Connor K, Safe S. 1993a. Immunotoxic potencies of polychlorinated biphenyl (PCB), dibenzofuran (PCDF) and dibenzo-p-dioxin (PCDD) congeners in C57BL/6 and DBA/2 mice. Toxicology 80:217–227. (As cited in ATSDR 2000.)8328002
Harper N, Howie L, Conner K, 1993b. Immunosuppressive effects of highly chlorinated biphenyls and diphenyl ethers on T-cell dependent and independent antigens in mice. Toxicology 85:123–135. (As cited in ATSDR 2000.)8303708
Hemming H, Flodstrom S, Warngard L, 1993. Relative tumour promoting activity of three polychlorinated biphenyls in rat liver. Eur J Pharmacol 248(2):163–174. (As cited in ATSDR 2000.)7901043
Hori M, Kondo H, Ariyoshi N, 1997. Changes in the hepatic glutathione peroxidase redox system produced by coplanar polychlorinated biphenyls in Ah-responsive and -less-responsive strains of mice: mechanism and implications for toxicity. Environ Toxicol Pharmacol 3:267–275. (As cited in ATSDR 2000.)21781787
Huisman M, Koopman-Esseboom C, Fidler V, 1995a. Perinatal exposure to polychlorinated biphenyls and dioxins and its effect on neonatal neurological development. Early Hum Dev 41:111–127. (As cited in ATSDR 2000.)7601016
Huisman M, Koopman-Essesboom C, Lanting CI, 1995b. Neurological condition in 18-month-old children perinatally exposed to polychlorinated biphenyls and dioxins. Early Hum Dev 43:165–176. (As cited in ATSDR 2000.)8903761
IARC. 1987. IARC monographs on the evaluation of the carcinogenic risk of chemicals to humans. Supplement 7: Overall evaluations of carcinogenicity: An updating of IARC monographs volumes 1 to 42. Lyon, France: World Health Organization. (As cited in ATSDR 2000.)
IRIS. 2000. Integrated Risk Information System. Polychlorinated biphenyls (PCBs). U.S. Environmental Protection Agency. http://www.epa.goc/ngispgm3/iris/subst/0294.htm. September 19, 2000.
Jacobson JL. 1985. Human exposure to PCBs--congeners and developmental effect. Crisp Data Base. National Institutes of Health. (As cited in ATSDR 2000.)
Jacobson JL, Jacobson SW. 1996. Intellectual impairment in children exposed to polychlorinated biphenyls in utero. N Engl J Med 335(11):783–789. (As cited in ATSDR 2000.)8703183
Jacobson JL, Jacobson SW, Humphrey HEB. 1990. Effects of in utero exposure to polychlorinated biphenyls and related contaminants on cognitive functioning in young children. J Pediatr 116(1):38–45. (As cited in ATSDR 2000.)2104928
Jacobson JL, Jacobson SW, Schwartz PM, 1984. Prenatal exposure to an environmental toxin: A test of the multiple effects model. Dev Psychol 20(4):523–532. (As cited in ATSDR 2000.)
Jansen HT, Cooke PS, Porcelli J, 1993. Estrogenic and antiestrogenic actions of PCBs in the female rat: In vitro and in vivo studies. Reprod Toxicol 7:237–248. (As cited in ATSDR 2000.)8318755
Jones CJ, Backlin BM, Stoddart RW, 1997. Environmental pollutants as aetiological agents in female reproductive pathology: Placental glycan expression in normal and polychlorinated biphenyl (PCB) - exposed mink (Mustela vison). Placenta 18(8):689–699. (As cited in ATSDR 2000.)9364605
Juarez de Ku LM, Sharma-Stokkermans M, Meserve LA. 1994. Thyroxine normalizes polychlorinated biphenyl (PCB) dose-related depression of choline acetyltransferase (ChAT) activity in hippocampus and basal forebrain of 15-day-old rats. Toxicology 94:19–30. (As cited in ATSDR 2000.)7801322
Kihlstrom JE, Olsson M, Jensen SJ, 1992. Effects of PCB and different fractions of PCB on the reproduction of the mink (Mustela vison). Ambio 21(8):563–569. (As cited in ATSDR 2000.)
Kodavanti PRS, Tilson HA. 1997. Structure-activity relationships of potentially neurotoxic PCB congeners in the rat. Neurotoxicology 18(2):425–442. (As cited in ATSDR 2000.)9291492
Kodavanti PRS, Derr-Yellin EC, Mundy WR, 1998. Repeated exposure of adult rats to Aroclor 1254 causes brain region-specific changes in intracellular Ca2+ buffering and protein kinase C activity in the absence of changes in tyrosine hydroxylase. Toxicol Appl Pharmacol 153:186–198. (As cited in ATSDR 2000.)9878590
Kodavanti PRS, Shin D-S, Tilson HA, 1993. Comparative effects of two polychlorinated biphenyl congeners on calcium homeostasis in rat cerebellar granule cells. Toxicol Appl Pharmacol 123:97–106. (As cited in ATSDR 2000.)8236268
Kodavanti PRS, Ward TR, McKinney JD, 1995. Increased [^3^H]phorbol ester binding in rat cerebellar granule cells by polychlorinated biphenyl mixtures and congeners: Structure-activity relationships. Toxicol Appl Pharmacol 130:140–148. (As cited in ATSDR 2000.)7839361
Kodavanti PRS, Ward TR, McKinney JD, 1996. Increased [^3^H]phorbol ester binding in rat cerebellar granule cells and inhibition of ^45^Ca^2+^ sequestration in rat cerebellum by polychlorinated diphenyl ether congeners and analogs: Structure-activity relationships. Toxicol Appl Pharmacol 138:251–261. (As cited in ATSDR 2000.)8658526
Koopman-Esseboom C, Morse DC, Weisglas-Kuperus N, 1994. Effects of dioxins and polychlorinated biphenyls on thyroid hormone status of pregnant women and their infants. Pediatr Res 36(4):468–473. (As cited in ATSDR 2000.)7816522
Koopman-Esseboom C, Weisglas-Kuperus N, de Ridder MAJ, 1996. Effects of polychlorinated biphenyl/dioxin exposure and feeding type on infants' mental and psychomotor development. Pediatrics 97(5):700–706. (As cited in ATSDR 2000.)8628610
Korach KS, Sarver P, Chae K, 1988. Estrogen receptor-binding activity of polychlorinated hydroxybiphenyls: Conformationally restricted structural probes. Mol Pharmacol 33:120–126.3122017
Kramer VJ, Helferich WG, Bergman A, 1997. Hydroxylated polychlorinated biphenyl metabolites are anti-estrogenic in a stably transfected human breast adenocarcinoma (MCF7) cell line. Toxicol Appl Pharmacol 144:363–374. (As cited in ATSDR 2000.)9194421
Krishnan V, Safe S. 1993. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), and dibenzofurans (PCDFs) as antiestrogens in MCF-7 human breast cancer cells: Quantitative structure-activity relationships. Toxicol Appl Pharmacol 120(1):55–61. (As cited in ATSDR 2000.)7685553
Larsen BR, Turrio-Baldassarri L, Nilsson T, 1994. Toxic PCB congeners and organochlorine pesticides in Italian human milk. Ecotoxicol Environ Saf 28:1–13. (As cited in ATSDR 2000.)7523063
Li M-H, Hansen LG. 1996a. Enzyme induction and acute endocrine effects in prepubertal female rats receiving environmental PCB/PCDF/PCDD mixtures. Environ Health Perspect 104(7):712–722. (As cited in ATSDR 2000.)8841756
Li M-H, Hansen LG. 1996b. Responses of prepubertal female rats to environmental PCBs with high and low dioxin equivalencies. Fundam Appl Toxicol 33:282–293. (As cited in ATSDR 2000.)8921347
Li M-H, Hansen LG. 1997. Consideration of enzyme and endocrine interactions in the risk assessment of PCBs. Rev Toxicol 1:71–156. (As cited in ATSDR 2000.)
Li M-H, Rhine C, Hansen LG. 1998. Hepatic enzyme induction and acute endocrine effects of 2,3,3',4',6'-pentachlorobiphenyl in prepubertal female rats. Arch Environ Contam Toxicol 35:97–103. (As cited in ATSDR 2000.)9601926
Linder RE, Gaines TB, Kimbrough RD. 1974. The effect of polychlorinated biphenyls on rat reproduction. Food Cosmet Toxicol 12:63–77. (As cited in ATSDR 2000.)4218577
Longcope C. 2000. The male and female reproductive systems in hypothyroidism. In: Braverman LE, Utiger RD, eds. Werner & Ingbar’s the thyroid: A fundamental and clinical text. Eighth edition. Philadelphia, PA: Lippincott Williams & Wilkins, 824–827. (As cited in ATSDR 2000.)
Lonky E, Reihman J, Darvill T, 1996. Neonatal behavioral assessment scale performance in humans influenced by maternal consumption of environmentally contaminated Lake Ontario fish. J Great Lakes Res 22(2):198–212. (As cited in ATSDR 2000.)
Lundkvist U. 1990. Clinical and reproductive effects of Clophen A50 (PCB) administered during gestation on pregnant guinea pigs and their offspring. Toxicology 6:249–257. (As cited in ATSDR 2000.)
Mariussen E, Anderson JM, Fonnum F. 1999. The effect of polychlorinated biphenyls on the uptake of dopamine and other neurotransmitters into rat brain synaptic vesicles. Toxicol Appl Pharmacol 161:274–282. (As cited in ATSDR 2000.)10620485
Mayes BA, McConnell EE, Neal BH, 1998. Comparative carcinogenicity in Sprague-Dawley rats of the polychlorinated biphenyl mixtures Aroclors 1016, 1242, 1254, and 1260. Toxicol Sci 41(1):62–76. (As cited in ATSDR 2000.)9520342
Moore M, Mustain M, Daniel K, 1997. Antiestrogenic activity of hydroxylated polychlorinated biphenyl congeners identified in human serum. Toxicol Appl Pharmacol 142:160–168. (As cited in ATSDR 2000.)9007045
Morse DC, Wehler EK, Wesseling W, 1996. Alterations in rat brain thyroid hormone status following pre- and postnatal exposure to polychlorinated biphenyls (Aroclor 1254). (As cited in ATSDR 2000.)
Nesaretnam K, Darbre P. 1997. 3,5,3',5'-Tetrachlorobiphenyl is a weak oestrogen agonist in vitro and in vivo. J Steroid Biochem Mol Biol 62(5/6):409–418. (As cited in ATSDR 2000.)
Nesaretnam K, Corcoran D, Dils RR, 1996. 3,4,3',4'-Tetrachlorobiphenyl acts as an estrogen in vitro and in vivo. Mol Endocrinol 923–936. (As cited in ATSDR 2000.)8843409
Ness DK, Schantz SL, Mostagian J, 1993. Perinatal exposure to two polychlorinated biphenyl congeners: Histological effects on the thyroid gland. Toxicologist 13(1):358. (As cited in ATSDR 2000.)
Parham FM, Portier CJ. 1998. Using structural information to create physiologically based pharmacokinetic models for all polychlorinated biphenyls. Toxicol Appl Pharmacol 151:110–116. (As cited in ATSDR 2000.)9705893
Patandin S, Dagnelie PC, Weisglas-Kuperus N, 1998a. Exposure to PCBs, PCDDs and PCDFs through breast milk compared with long-term dietary exposure. Organohalogen Compounds 38:214A–214F. (As cited in ATSDR 2000.)
Patandin S, Koopman-Esseboom C, De Ridder MAJ, 1998b. Effects of environmental exposure to polychlorinated biphenyls and dioxins on birth size and growth in Dutch children. Pediatr Res 44(4):538–545. (As cited in ATSDR 2000.)9773843
Patandin S, Lanting CI, Mulder PGH, 1999. Effects of environmental exposure to polychlorinated biphenyls and dioxins on cognitive abilities in Dutch children at 42 months of age. J Pediatr 134:33–41. (As cited in ATSDR 2000.)9880446
Patnode KA, Curtis LR. 1994. 2,2',4,4',5,5'- and 3,3',4,4',5,5'-Hexachlorobiphenyl alteration of uterine progesterone and estrogen receptors coincides with embryotoxicity in mink (Mustela vison). Fundam Appl Toxicol 127:9–18. (As cited in ATSDR 2000.)
Poland A, Knutson JC. 1982. 2,3,7,8-Tetrachlorodibenzo-p-dioxin and related halogenated aromatic hydrocarbons. Examinations of the mechanisms of toxicity. Annu Rev Pharmacol Toxicol 22:517–554. (As cited in ATSDR 2000.)6282188
Porterfield SP, Hendry LB. 1998. Impact of PCBs on thyroid hormone directed brain development. Toxicol Ind Health 14:103–120. (As cited in ATSDR 2000.)9460172
Provost TL, Juarez De Ku LM, Zender C, 1999. Dose- and age-dependent alterations in choline acetyltransferase (ChAT) activity, learning and memory, and thyroid hormones in 15- and 30-day old rats exposed to 1.25 or 12.5 ppm polychlorinated biphenyl (PCB) beginning at conception. Prog Neuro-Psychopharmacol Biol Psychiat 23:915–928. (As cited in ATSDR 2000.)
Preston BD, Miller EC, Miller JA. 1985. The activities of 2,2',5,5'-tetrachlorobiphenyl, its 3,4-oxide metabolite, and 2,2',4,4'-tetrachlorobiphenyl in tumor induction and promotion assays. Carcinogenesis 6(3):451–453. (As cited in ATSDR 2000.)2858273
Rice DC. 1997. Effect of postnatal exposure to a PCB mixture in monkeys on multiple fixed interval-fixed ratio performance. Neurotoxicol Teratol 19(6):429–434. (As cited in ATSDR 2000.)9392778
Rice DC. 1998. Effects of postnatal exposure of monkeys to a PCB mixture on spatial discrimination reversal and DRL performance. Neurotoxicol Teratol 20(4):391–400. (As cited in ATSDR 2000.)9697965
Rice DC. 1999. Behavioral impairment produced by low-level postnatal PCB exposure in monkeys. Environ Res 80:S113–S121. (As cited in ATSDR 2000.)10092425
Rice DC, Hayward S. 1997. Effects of postnatal exposure to a PCB mixture in monkeys on nonspatial discrimination reversal and delayed alternation performance. Neurotoxicology 18(2):479–494. (As cited in ATSDR 2000.)9291496
Rice DC, Hayward S. 1999. Effects of exposure to 3,3',4,4',5-pentachlorobiphenyl (PCB 126) throughout gestation and lactation on behavior (concurrent random interval-random interval and progressive ratio performance) in rats. Neurotoxicol Teratol 21(6):679–687. (As cited in ATSDR 2000.)10560775
Robertson LW, Gupta RC. 2000. Metabolism of polychlorinated biphenyls (PCBs) generates electrophiles and reactive oxygen species that damage DNA. In: Williams GM, Aruoma OI, eds. Molecular drug metabolism and toxicology. OICA International, 1–19. (As cited in ATSDR 2000.)
Rogan WJ, Gladen BC, McKinney JD, 1986a. Neonatal effects of transplacental exposure to PCBs and DDE. J Pediatr 109:335–341. (As cited in ATSDR 2000.)3090217
Rogan WJ, Gladen BC, McKinney JD, 1986b. Polychlorinated biphenyls (PCBs) and dichlorophenyl dichloroethene (DDE) in human milk: Effects of maternal factors and previous lactation. Am J Public Health 76:172–177. (As cited in ATSDR 2000.)3080910
Rogan WJ, Gladen BC, McKinney JD, 1987. Polychlorinated biphenyls (PCBs) and dichlorodiphenyl dichloroethene (DDE) in human milk: Effects on growth, morbidity, and duration of lactation. Am J Public Health 77:1294–1297. (As cited in ATSDR 2000.)3115123
Ross PS, De Swart RL, Reijnders PJH, 1995. Contaminant-related suppression of delayed-type hypersensitivity and antibody responses in harbor seals fed herring from the Baltic Sea. Environ Health Perspect 103(2):162–167. (As cited in ATSDR 2000.)7737064
Rylander L, Hagmar L. 1999. Anthropometric and psychometric examinations of conscripts born to mothers with a high intake of fish contaminated with persistent organochlorines. In: Dioxin 99: International Symposium on halogenated environmental organic pollutants and POPs. Organohalogen Compounds 44:413–416. (As cited in ATSDR 2000.)
Rylander L, Stromberg U, Dyremark E, 1998a. Polychlorinated biphenyls in blood plasma among Swedish female fish consumers in relation to low birth weight. Am J Epidemiol 147(5):493–502. (As cited in ATSDR 2000.)9525537
Rylander L, Stromberg U, Hagmar L. 1995. Decreased birthweight among infants born to women with a high dietary intake of fish contaminated with persistent organochlorine compounds. Scand J Work Environ Health 21:368–375. (As cited in ATSDR 2000.)8571093
Rylander L, Stromberg U, Hagmar L. 1996. Dietary intake of fish contaminated with persistent organochlorine compounds in relation to low birthweight. Scand J Work Environ Health 22:260–266. (As cited in ATSDR 2000.)8881014
Rylander L, Stromberg U, Hagmar L. 1998b. Lowered birthweight among infants born to women with high intake of fish contaminated with persistent organochlorine compounds. In: Organohalogen Compounds 38:275–277. (As cited in ATSDR 2000.)
Safe S. 1984. Polychlorinated biphenyls (PCBs) and polybrominated biphenyls (PBBs): Biochemistry, toxicology, and mechanism of action. CRC Crit Rev Toxicol 13:319–395. (As cited in ATSDR 2000.)
Safe S. 1990. Polychlorinated biphenyls (PCBs), dibenzo-p-dioxins (PCDDs), dibenzofurans (PCDFs), and related compounds: Environmental and mechanistic considerations which support the development of toxic equivalency factors (TEFs). Crit Rev Toxicol 21:51–88. (As cited in ATSDR 2000.)2124811
Safe S. 1994. Polychlorinated biphenyls (PCBs): Environmental impact, biochemical and toxic responses, and implications for risk assessment. Crit Rev Toxicol 24(2):87–149. (As cited in ATSDR 2000.)8037844
Safe S. 1998a. Development validation and problems with the toxic equivalency factor approach for risk assessment of dioxins and related compounds. J Anim Sci 76(1):134–141. (As cited in ATSDR 2000.)9464894
Safe S. 1998b. Limitations of the toxic equivalency factor approach for the risk assessment of TCDD and related compounds. Teratogen Carcinogen Mutagen 17:285–304. (As cited in ATSDR 2000.)
Safe S. 1999. 2,3,7,8-Tetrachlorodibenzo-p-dioxin (TCDD) and related environmental antiestrogens: Characterization and mechanism of action. In: Naz RK, ed. Endocrine disruptors: effects on male and female reproductive systems. Boca Raton, FL: CRC Press, 187–221. (As cited in ATSDR 2000.)
Sager DB, Girard DM. 1994. Long-term effects on reproductive parameters in female rats after translactational exposure to PCBs. Environ Res 66(1):52–76. (As cited in ATSDR 2000.)8013438
Sager D, Girard D, Nelson D. 1991. Early postnatal exposure to PCBs: Sperm function in rats. Environ Toxicol Chem 10:737–746. (As cited in ATSDR 2000.)
Sager DB, Shih-Schroeder W, Girard D. 1987. Effect of early postnatal exposure to polychlorinated biphenyls (PCBs) on fertility in male rats. Bull Environ Contam Toxicol 38:946–953. (As cited in ATSDR 2000.)3107640
Schantz SL, Seo B-W, Wong PW, 1997. Long-term effects of developmental exposure to 2,2',3,5',6-pentachlorobiphenyl (PCB 95) on locomotor activity, spatial learning and memory and brain ryanodine binding. Neurotoxicol 18(2):457–468. (As cited in ATSDR 2000.)
Schuur AG, Bergman A, Brouwer A, 1999. Effects of pentachlorophenol and hydroxylated polychlorinated biphenyls on thyroid hormone conjugation in a rat and a human hepatoma cell line. Toxicol in Vitro 13:417–425. (As cited in ATSDR 2000.)20654499
Schuur AG, Cenjin PH, van Toor H, 1998a. Effect of Aroclor 1254 on thyroid hormone sulfation in fetal rats. Organohalogen Compounds 37:249–252. (As cited in ATSDR 2000.)
Schuur AG, van Leeuwen-Bol I, Jong WMC, 1998b. In vitro inhibition of thyroid hormone sulfation by polychloribiphenylols: Isozyme specificity and inhibition kinetics. Toxicol Sci 45:188–194. (As cited in ATSDR 2000.)9848125
Seegal RF. 1996. Epidemiological and laboratory evidence of PCB-induced neurotoxicity. Crit Rev Toxicol 26(6):709–737. (As cited in ATSDR 2000.)8958469
Seegal RF. 1998. Neurochemical effects of co-planar and non-coplanar polychlorinated biphenyls. [Abstract]. Neurotoxicol Teratol 20(3):349–350. (As cited in ATSDR 2000.)
Seegal RF, Brosch K, Bush B 1989. Effects of Aroclor 1254 on dopamine and norepinephrine concentrations in pheochromocytoma (PC-12) cells. Neurotoxicology 10:757–764. (As cited in ATSDR 2000.)2562550
Seegal RF, Brosch KO, Okoniewski RJ. 1997. Effects of in utero and lactational exposure of the laboratory rat to 2,4,2'4'-tetrachlorobiphenyl on dopamine function. Toxicol Appl Pharmacol 146(1):95–103. (As cited in ATSDR 2000.)9299601
Seegal RF, Bush B, Shain W. 1990. Lightly chlorinated ortho-substituted PCB congeners decrease dopamine in nonhuman primate brain and in tissue culture. Toxicol Appl Pharmacol 106:136–144. (As cited in ATSDR 2000.)2123577
Seiler P, Fischer B, Lindenau A, 1994. Effects of persistent chlorinated hydrocarbons on fertility and embryonic development in the rabbit. Human Reprod 9:1920–1926. (As cited in ATSDR 2000.)
Seo BW, Meserve LA. 1995. Effects of maternal ingestion of Aroclor 1254 (PCB) on the developmental pattern of oxygen consumption and body temperature in neonatal rats. Bull Environ Contam Toxicol 55:22–28. (As cited in ATSDR 2000.)7663088
Shain W, Bush B, Seegal R. 1991. Neurotoxicity of polychlorinated biphenyls: Structure-activity relationship of individual congeners. Toxicol Appl Pharmacol 111:33–42. (As cited in ATSDR 2000.)1949034
Silberhorn EM, Glauert HP, Robertson LW. 1990. Carcinogenicity of polyhalogenated biphenyls: PCBs and PBBs. Crit Rev Toxicol 20:440–496. (As cited in ATSDR 2000.)2165409
Silkworth JB, Grabstein EM. 1982. Polychlorinated biphenyl immunotoxicity: Dependence on isomer planarity and the Ah gene complex. Toxicol Appl Pharmacol 65:109–115. (As cited in ATSDR 2000.)6815831
Smith AG, Francis JE, Carthew P. 1990a. Iron as a synergist for hepatocellular carcinoma induced by polychlorinated biphenyls in Ah-responsive C57BL/10ScSn mice. Carcinogenesis 11(3):437–444. (As cited in ATSDR 2000.)2155720
Smith AG, Francis JE, Green JA, 1990b. Sex-linked hepatic uroporphyria and the induction of cytochromes P450IA in rats caused by hexachlorobenzene and polyhalogenated biphenyls. Biochem Pharmacol 40(9):2059–2068. (As cited in ATSDR 2000.)2173599
Stack AS, Altman-Hamamdzic S, Morris PJ, 1999. Polychlorinated biphenyl mixtures (Aroclors) inhibit LPS-induced murine splenocyte proliferation in vitro. Toxicology 139:137–154. (As cited in ATSDR 2000.)10614695
Stewart P, Darvill T, Lonky E, 1999. Assessment of prenatal exposure to PCBs from maternal consumption of Great Lakes fish: An analysis of PCB patter and concentration. Environ Res 80:S87–S96. (As cited in ATSDR 2000.)10092422
Stewart P, Reihman J, Lonky E, 2000. Prenatal PCB exposure and neonatal behavioral assessment scale (NBAS) performance. Neurotoxicol Teratol 22:21–29. (As cited in ATSDR 2000.)10642111
Svensson B-G, Hallberg T, Nilsson A, 1994. Parameters of immunological competence in subjects with high consumption of fish contaminated with persistent organochlorine compounds. Int Arch Occup Environ Health 65:351–358. (As cited in ATSDR 2000.)8034358
Swanson GM, Ratcliffe HE, Fischer LJ. 1995. Human exposure to polychlorinated biphenyls (PCBs): A critical assessment of the evidence for adverse health effects. Regul Toxicol Pharmacol 21:136–150. (As cited in ATSDR 2000.)7784626
Tilson HA, Kodavanti PRS. 1997. Neurochemical effects of polychlorinated biphenyls: An overview and identification of research needs. Neurotoxicology 18(3):727–744. (As cited in ATSDR 2000.)9339820
Tilson HA, Kodavanti PRS. 1998. The neurotoxicity of polychlorinated biphenyls. Neurotoxicology 19(4–5):517–526. (As cited in ATSDR 2000.)9745906
Tilson HA, Kodavanti PRS, Mundy WR, 1998. Neurotoxicity of environmental chemicals and their mechanism of action. Toxicol Lett 102–103:631–635. (As cited in ATSDR 2000.)
Tithof PK, Contreras ML, Ganey PE. 1995. Aroclor 1242 stimulates the production of inositol phosphates in polymorphonuclear neutrophils. Toxicol Appl Pharmacol 131:136–143. (As cited in ATSDR 2000.)7878669
Tryphonas L, Arnold DL, Zawidzka Z, 1986a. A pilot study in adult Rhesus monkeys (m.mullata) treated with Aroclor 1254 for two years. Toxicol Pathol 14:1–10. (As cited in ATSDR 2000.)3086960
Tryphonas L, Charbonneau S, Tryphonas H, 1986a. Comparative aspects of Aroclor 1254^®^ toxicity in adult Cynomolgus and Rhesus monkeys: A pilot study. Arch Environ Contam Toxicol 15:159–169. (As cited in ATSDR 2000.)3085600
Tryphonas H, Hayward S, O'Grady L, 1989. Immunotoxicity studies of PCB (Aroclor 1254) in the adult Rhesus (Macaca mulatta) monkey-preliminary report. Int J Immunopharmacol 11(2):199–206. (As cited in ATSDR 2000.)2495254
Tryphonas H, Luster MI, Schiffman G, 1991. Effect of chronic exposure of PCB (Aroclor 1254) on specific and nonspecific immune parameters in the Rhesus (Macaca mulatta) monkey. Fundam Appl Toxicol 16:773–786. (As cited in ATSDR 2000.)1884915
Van Birgelen APJM, Van Der Kolk J, Fase KM, 1994. Toxic potency of 3,3',4,4',5-pentachlorobiphenyl relative to and in combination with 2,3,7,8-tetrachlorodibenzo-p-dioxin in a subchronic feeding study in the rat. Toxicol Appl Pharmacol 127:209–221. (As cited in ATSDR 2000.)8048064
Van Birgelen APJM, Van der Kolk J, Fase KM, 1995. Subchronic dose-response study of 3,4,7,8-tetrachlorodibenzo-p-dioxin in female Sprague-Dawley rats. Toxicol Appl Pharmacol 132:1–13 (As cited in ATSDR 2000.)7747272
Van Birgelen APJM, Van der Kolk J, Poiger H, 1992. Interactive effects of 2,2',4,4',5,5'-hexachlorobiphenyl and 2,3,7,8-tetrachlorodibenzo-p-dioxin on thyroid hormone, Vitamin A, and Vitamin K metabolism in the rat. Chemosphere 25:7–10. (As cited in ATSDR 2000.)
Van den Berg M, Birnbaum L, Bosveld ATC, 1998. Toxic equivalency factors (TEFs) for PCBs, PCDDs, PCDFs for humans and wildlife. Environ Health Perspect 106(12):775–792. (As cited in ATSDR 2000.)9831538
Van der Burght ASAM, Clijsters PJ, Horbach GJ, 1999. Structure-dependent induction of CYP1A by polychlorinated biphenyls in hepatocytes of Cynomolgus monkeys (Macaca fascicularis). Toxicol Appl Pharmacol 155:13–23. (As cited in ATSDR 2000.)10036214
van der Plas SA, Haag-Gronlund M, Scheu G, 1999. Induction of altered hepatic foci by a mixture of dioxin-like compounds with and without 2,2',4,4',5,5'-hexachlorobiphenyl in female Sprague-Dawley rats. Toxicol Appl Pharmacol 156:30–39. (As cited in ATSDR 2000.)10101096
Welsch F. 1985. Effects of acute or chronic polychlorinated biphenyl ingestion on maternal metabolic homeostasis and on the manifestations of embryotoxicity caused by cyclophosphamide in mice. Arch Toxicol 57:104–113. (As cited in ATSDR 2000.)3927875
Wong PW, Pessah IN. 1996. Ortho-substituted polychlorinated biphenyls alter calcium regulation by a ryanodine receptor-mediated mechanism: Structural specificity toward skeletal- and cardiac-type microsomal calcium release channels. Mol Pharmacol 49:740–751. (As cited in ATSDR 2000.)8609904
Wong PW, Pessah IN. 1997. Noncoplanar PCB 95 alters microsomal calcium transport by an immunophilin FKBP 12-dependent mechanism. Mol Pharmacol 51:693–702. (As cited in ATSDR 2000.)9145907
Wong PW, Joy RM, Albertson TE, 1997. Ortho-substituted 2,2',3,5',6-pentachlorobiphenyl (PCB 95) alters rat hippocampal ryanodine receptors and neuroplasticity in vitro: Evidence for altered hippocampal function. Neurotoxicology 18(2):443–456. (As cited in ATSDR 2000.)9291493
Zoeller RT, Dowling ALS, Vas AA. 2000. Developmental exposure to polychlorinated biphenyls exerts thyroid hormone-like effects on the expression of RC3/neurogranin and myelin basic protein messenger ribonucleic acids in the developing rat brain. Endocrinology 141(1):181–189. (As cited in ATSDR 2000.)10614638