# Appendix C Background Information for Cesium

Cesium is a naturally occurring element that exists in the environment as the free metal and in the (I) oxidation state. Because the biological availability and toxicity of cesium are primarily related to the cesium(I) oxidation state, ATSDR (2001c) has focused on that form of cesium. While a number of radioisotopes of cesium exist, the most common are ^137^Cs and ^134^Cs. As such, ATSDR (2001c) has chosen to focus primarily on radiation from these two isotopes when discussing radioactive cesium.

## C.1 Toxicokinetics

Numerous toxicokinetic studies have been performed in animals exposed to small quantities of the radioisotope cesium-137. The biokinetic behavior of cesium has also been studied in humans either given tracer amounts of radiolabeled cesium or accidently exposed to larger amounts (ATSDR 2001c).

Inhaled or ingested cesium (in soluble compounds) is rapidly absorbed and widely distributed to all major tissues and organs (ATSDR 2001c). Insoluble airborne particles containing cesium may be retained in lung tissues and slowly cleared, but they do not appear to be absorbed in any significant amounts. Insoluble particles that are ingested are mostly excreted in the feces; human and animal studies indicate that only a small percentage of the ingested material is absorbed. Some degree of dermal absorption occurs, as demonstrated by qualitative findings of internalized radioactivity from compounds containing radioactive cesium following dermal exposure in humans and animals.

Following absorption, widespread distribution of cesium to all major soft tissues is observed in humans and animals, cesium levels being slightly higher in skeletal muscle than other tissues (ATSDR 2001c). Distribution patterns in animals have been shown to be similar following exposure by inhalation, oral, and parenteral routes of exposure. Cesium crosses the placenta and can be found in breast milk.

No reports were located regarding metabolism of cesium in humans or animals (ATSDR 2001c). However, cesium behaves in a manner similar to potassium, both elements being more highly concentrated in intracellular fluid. Cesium can replace potassium in biological systems, and cesium retention has been experimentally estimated based on elimination rates of potassium.

Excretory rates of cesium-137 have been studied in numerous populations exposed via fallout following nuclear incidents such as the Chernobyl accident, and models have been developed to describe relationships between intake and elimination (ATSDR 2001c). Experimental human studies have also been performed using tracer amounts of radioisotopes of cesium. Urinary excretion is the primary route of elimination of cesium, independent of the route of exposure. Urinary:fecal ratios in humans have been found to range from 2.5:1 to 10:1. Radiolabeled cesium excretory rates were lower in males suffering from muscular dystrophy than in age-matched controls (ATSDR 2001c).

Elimination of cesium in humans appears to be age- and sex-related and may be principally a function of body mass. Children ages 5–14 exhibited average elimination half-lives for cesium of 20 days, with no significant difference between males and females; elimination half-lives in older groups were significantly higher (47 days for adolescent and adult females; 67 days in 15-year-old males; 93 days in males 30–50 years of age).

## C.2 Health Effects

Stable Cesium. No reports were located regarding health effects in humans or animals following inhalation exposure to potentially hazardous concentrations of stable cesium (ATSDR 2001c). Data on exposure to stable cesium by the dermal route are also lacking, with the only available studies being of acute duration and limited in scope.

Neulieb (1984) reported a case of a human who ingested about 34 mg Cs/kg (as cesium chloride) after morning and evening meals (68 mg Cs/kg/day) for 36 days. Self-reported gastrointestinal effects included decreased appetite, nausea, and diarrhea. The human reported experiencing, within 15 minutes of ingestion, general feelings of well-being, heightened sense perception, and tingling sensations in lips, cheeks, hands, and feet. No self-reported adverse effects were noted in performance of mathematical tasks or in automobile driving skill. Other examinations of the effects of stable cesium after oral exposure are limited to acute toxicity studies in animals.

Radioactive Cesium. No reports were located regarding health effects in animals following acute-, intermediate-, or chronic-duration inhalation or dermal exposure to radiocesium. Information regarding adverse effects following oral exposure is limited to two studies in which significantly reduced fertility and temporary sterility were observed in male mice following single or repeated oral administration of radioactive cesium nitrate; post-mating embryo mortality was associated with increased frequency of dominant lethal mutations (Ramaiya et al. 1994).

Adverse neurological, developmental, reproductive, genotoxic, and cancer effects have been observed in animal studies employing external exposure to radioactive cesium sources. Impaired motor activity, decreased thickness of cortical layers of the brain, and increased aggressive behavior were observed after the birth of rats that had been briefly exposed in utero to relatively high (0.75–1.0 Sv) levels of external radiation from a cesium-137 source (Minamisawa et al. 1992; Norton and Kimler 1987, 1988). The most vulnerable developmental period was around gestational days 14–15. In another study, adverse developmental effects in fetal rats irradiated with 400 Sv on gestational day 12 included reduced litter size, smaller head size, retarded odontogenesis, and cleft palate when examined on gestational day 18 (Saad et al. 1991, 1994). Significant increases in the formation rate of micronuclei were seen in blood cells of other fetal rats following irradiation (50 Sv) of pregnant dams via a cesium-137 source on gestational day 14 (Koshimoto et al. 1994). Significantly reduced fertility (including temporary sterility) was reported in male mice exposed to an external cesium-137 source for almost 20 days (300 Sv total dose); an increased frequency of dominant lethal mutations was also indicated by increased post-mating embryo mortality (Ramaiya et al. 1994). Increased lifetime risk of mammary tumors was noted in female rats that were exposed to single whole-body doses of 100 Sv of radiation from a cesium-137 source between the ages of 8 and 36 weeks (Bartstra et al. 1998). Irradiation at 64 weeks, however, yielded fewer carcinomas than unirradiated controls.

## C.3 Mechanisms of Action

Stable Cesium. Due to the relatively low abundance of stable cesium in the environment, its limited use in industry, and the lack of cesium-induced toxicity in animal studies, stable cesium is not likely to be of toxic concern to humans exposed to cesium by inhalation, oral, or dermal contact. Although a number of investigators have reported cesium-induced alterations in behavior or cardiac activity in animals systems exposed to cesium chloride via parenteral injection or using in vitro methods, the underlying mechanisms are not yet fully understood.

Cesium appears to have both depressant and anti-depressant properties in rodents, attenuating the conditioned avoidance response of pole-climbing (Bose and Pinsky 1983) and reducing vertical and horizontal motor activity (Bose and Pinsky 1981, 1984; Bose et al. 1981; Pinsky et al. 1980), and enhancement of amphetamine-induced hyperactivity and reducing the locomotor depressive action of reserpine (Messiha 1978).

Increased vertical activity (rearing), but not horizontal activity (locomotion), was observed in mice given repeated injections of stable cesium chloride (Johnson 1972). Rastogi et al. (1980) found no increase in behavioral activity in rats repeatedly injected with stable cesium chloride, but noted a number of biochemical changes in the brain that included a significant rise in tyrosine hydroxylase activity that resulted in a slight but significant increase in tyrosine levels, markedly enhanced levels of the neurotransmitters norepinephrine and dopamine, and increased levels of a norepinephrine metabolite (4-hydroxy-3-methoxyphenylglycol). Cesium appeared to significantly block the uptake of norepinephrine by synaptosomes.

Cesium has been shown to trigger short-lived early afterdepolarizations (EADs) and polymorphic ventricular tachyrhythmias (VTs) in canine myocardial muscle fibers and Purkinje cells (Brachmann et al. 1983; Levine et al. 1985; Murakawa et al. 1997; Patterson et al. 1990), effects that are similar to those observed in humans with congenital and acquired long Q-T syndrome (Bonatti et al. 1983). Although the mechanisms responsible for these effects have not been elucidated, available animal data suggest that cesium-induced EADs and VTs are most likely the result of ionic imbalance due to reduced potassium permeability (Isenberg 1976) and/or imbalances of intra- and extracellular concentrations of calcium and sodium (Szabo et al. 1987).

Radioactive Cesium. Due to its ionizing radiation, radioactive cesium may present a significant health hazard. Highly-penetrating gamma emission is the major source of damage to tissues and internal organs following external exposure to radioactive cesium isotopes (ATSDR 2001c). Once radioactive cesium is internalized, nearby tissues are at highest risk for damage due to the release of beta particles. In either case, exposure to ionizing radiation results in significant risk of cellular damage. Ionized molecules within irradiated cells may be repaired quickly to prevent further damage. On the other hand, irreparable damage may be imposed on cellular materials, such as DNA, which might ultimately result in the formation of cancerous tumors. Very large acute radiation doses can damage or kill enough cells to cause the disruption of organ systems, resulting in acute radiation sickness in developing fetuses, and even death. Limited human and animal data indicate that exposure to radioactive cesium can result in adverse effects such as reduced fertility, abnormal neurological development, genotoxicity, and possibly cancer (ATSDR 2001c). For a more complete discussion of the mechanisms associated with the toxic effects of ionizing radiation, refer to Chapter 5 of the Toxicological Profile for Ionizing Radiation (ATSDR 1999).

## C.4 Health Guidelines

ATSDR (2001c) did not derive oral or inhalation MRLs for cesium due to lack of available data.

ATSDR (2001c) did not derive MRLs specific for external exposure to cesium radiation. The MRLs for external exposure to ionizing radiation derived in the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999) are applicable to cesium. The acute MRL of 0.004 Sv is based on neurodevelopmental effects in humans irradiated in utero during the atomic bombings of Hiroshima or Nagasaki. The chronic MRL for ionizing radiation is based on the average yearly background dose of ionizing radiation (ATSDR 1999).

The EPA considers all radionuclides to be cancer classification A (known human carcinogen), and has derived carcinogenic slope factors for inhalation, oral, and external exposure to radiocesium isotopes (EPA 1997). For the most commonly-occurring isotope, ^137^Cs, the cancer slope factor for ingestion exposure is 3.16×10^−11^ pCi^−1^.

## C.5 Derivation of Target-Organ Toxicity Dose (TTD) Values

As the available data from the sites of concern report that the vast majority of cesium contamination in these sites consists of radiocesium (mainly cesium-137), the TTD values below are based upon radiocesium and cesium radiation. TTDs for chronic oral exposure to radiocesium mixtures were derived for endpoints affected by radiostrontium and one or more of the other chemicals in strontium-cobalt-cesium-trichloroethylene-PCB mixture that is the subject of this Interaction Profile. The relevant endpoints for radiocesium in this mixture include hematological, immunological, developmental, neurologic, and hepatic endpoints. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (2001d), and in particular, the oral LSE table.

### Hematological Effects

Exposed persons from the Techa River population exhibited alterations in hematological parameters, including thrombocytopenia (Akleyev et al. 1995). These effects were observed in a portion of the exposed population that received radiation doses to the bone marrow at rates in excess of 30–50 rem (0.3–0.5 Sv) per year. While the bulk of this exposure is believed to have come from radiostrontium, the role of radiation from cesium compounds cannot be ruled out. The 0.3 Sv/year level (utilized as a LOAEL), converted to 8×10^−4^ Sv/day, and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for intrahuman variability) was used to derive a TTD_HEMATO_ of 8×10^−6^ Sv/day.

### Immunological Effects

Exposed persons from the Techa River population exhibited alterations in immunological parameters, including leukopenia and granulocytopenia (Akleyev et al. 1995). These effects were observed in a portion of the exposed population that received radiation doses to the bone marrow at rates in excess of 30–50 rem (0.3–0.5 Sv) per year. While the bulk of this exposure is believed to have come from radiostrontium, the role of radiation from cesium compounds cannot be ruled out. The 0.3 Sv/year level (utilized as a LOAEL), converted to 8×10^−4^ Sv/day, and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for intrahuman variability) was used to derive a TTD_IMMUNO_ of 8×10^−6^ Sv/day.

### Reproductive Effects

Ramaija et al. (1994) identified a NOAEL of 154 Sv and a LOAEL of 385 Sv for temporarily sterility in male mice exposed once per day for 14 days external cesium radiation. To the NOAEL of (154 Sv/14 days = 11 Sv/day), an uncertainty factor of 100 (10 for animal to human extrapolation, 10 for intrahuman variability) to derive the TTD_REPRO_ of 0.1 Sv/day.

### Neurological Effects

Available studies with radiocesium compounds or cesium radiation suggest that the nervous system is only affected by cesium or cesium radiation at very high radiation doses or when exposure occurs during the development of the nervous system in utero (ATSDR 2001c). No TTD was derived.

### Developmental Effects

ATSDR (1999) has derived an acute-duration (14 days or less) MRL of 0.004 Sv for exposure to ionizing radiation, based on neurodevelopmental effects (decreased IQ scores) in humans exposed in utero during the atomic bombing of Hiroshima and Nagasaki. This number is therefore adopted as the TTD for developmental effects of cesium radiation.

### Hepatic Effects

Data on the hepatic effects of oral or external exposure to radiocesium compounds are not available. No TTD was derived.

### Summary (TTDs for Cesium)

TTD_HEMATO_ = 8×10^−6^ Sv/day (dose localized to bone marrow)

TTD_IMMUNO_ = 8×10^−6^ Sv/day (dose localized to bone marrow)

TTD_REPRO_ = 0.1 Sv/day (total body dose)

TTD_DEVELOP_ = 4×10^−3^ Sv (total body dose)

TTD_NEURO_ = Not applicable

TTD_HEPATIC_ = Not applicable

## C.6 References

Akleyev AV, Kossenko MM, Silkina LA, 1995. Health effects of radiation incidents in the Southern Urals. Stem Cells 13(Suppl 1):58–68. (As cited in ATSDR 2001c.)7488969
ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001a. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
ATSDR. 2001d. Toxicological profile for cobalt. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001c. Toxicological profile for cesium. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Bartstra RW, Bentvelzen PAJ, Zoetelief J, 1998. Induction of mammary tumors in rats by single-dose gamma irradiation at different ages. Radiat Res 150:442–450. (As cited in ATSDR 2001c.)9768859
Bonatti V, Rolli A, Botti G. 1983. Recording of nonphasic action potentials of the right ventricle in long QT syndromes complicated by severe ventricular arrhythmias. Eur Heart J 4:168–179. (As cited in ATSDR 2001c.)6190653
Bose R, Pinsky C. 1981. Cesium impairs conditioned avoidance response (CAR) in mice and rats. Proc Can Fed Biol Soc 24:101. (As cited in ATSDR 2001c.)
Bose R, Pinsky C. 1983. Cesium attenuates conditioned avoidance response in rats and mice. Pharmacol Biochem Behav 18:867–871. (As cited in ATSDR 2001c.)6889415
Bose R, Pinsky C. 1984. Central depressant action of cesium in mice. Psychopharmacology 84:80–84. (As cited in ATSDR 2001c.)6436894
Bose R, Pinsky C, Jasper SC, 1981. Cesium on acquisition of conditioned avoidance response (CAR) and motor behavior in mice. Pharmacologist 23:151. (As cited in ATSDR 2001c.)
Brachmann J, Scherlag BJ, Rosenshtraukh LV, 1983. Bradycardia-dependent triggered activity: relevance to drug-induced multiform ventricular tachycardia. Circulation 68(4):846–856. (As cited in ATSDR 2001c.)6616779
EPA. 1997. Health effects assessment summary tables: FY 1997 update. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Emergency and Remedial Response. NTIS PB97–921199. (As cited in ATSDR 2001c.)
Isenberg G. 1976. Cardiac purkinje fibers: Cesium as a tool to block inward rectifying potassium currents. Pflugers Arch 365:99–106. (As cited in ATSDR 2001c.)988568
Johnson FN. 1972. Effects of alkali metal chlorides on activity in rats. Nature 238:333–334. (As cited in ATSDR 2001c.)4561839
Koshimoto C, Takahashi S, Kubota Y, 1994. Evaluation of the effect of gamma-irradiation on fetal erythropoiesis in rats using blood cell volume as the index. J Radiat Res 35:74–82. (As cited in ATSDR 2001c.)7965992
Levine JH, Spear JF, Guarnieri T, 1985. Cesium chloride-induced long QT syndrome: Demonstration of after depolarizations and triggered activity in vivo. Circulation 72(5):1092–1103. (As cited in ATSDR 2001c.)4042297
Messiha FS. 1978. Anti-depressant action of caesium chloride and its modification of chlorpromazine toxicity in mice. Br J Pharmacol 64:9–12. (As cited in ATSDR 2001c.)698485
Minamisawa T, Hirokaga K, Sasaki S, 1992. Effects of fetal exposure to gamma rays on aggressive behavior in adult male mice. J Radiat Res 33:243–249. (As cited in ATSDR 2001c.)1464856
Murakawa Y, Sezaki K, Yamashita T, 1997. Three-dimensional activation sequence of cesium-induced ventricular arrhythmias. Am J Physiol 42:H1377–H1385. (As cited in ATSDR 2001c.)
Neulieb R. 1984. Effects of oral intake of cesium chloride: A single case report. Pharmacol Biochem Behav 21(1):15–16. (As cited in ATSDR 2001c.)6522428
Norton S, Kimler BF. 1987. Correlation of behavior with brain damage after in utero exposure to toxic agents. Neurotoxicol Teratol 9:145–150. (As cited in ATSDR 2001c.)3657750
Norton S, Kimler BF. 1988. Comparison of functional and morphological deficits in the rat after gestational exposure to ionizing radiation. Neurotoxicol Teratol 10:363–371. (As cited in ATSDR 2001c.)3226380
Patterson E, Szabo B, Scherlag BJ, 1990. Early and delayed after depolarizations associated with cesium chloride-induced arrhythmias in the dog. J Cardiovasc Pharmacol 15:323–331. (As cited in ATSDR 2001c.)1689430
Pinsky C, Bose R, Dua AK, 1980. Interdisciplinary studies on brain level determination and behavioral effects of cesium (Cs). Pharmacologist 22(3):158. (As cited in ATSDR 2001c.)
Ramaiya LK, Pomerantseva MD, Chekhovich AV, 1994. Genetic effects of testicular incorporation of ^137^Cs in mice. Mutat Res 324:139–145. (As cited in ATSDR 2001c.)7519738
Rastogi RB, Singhal RL, Lapierre YD. 1980. Effects of rubidium and cesium on central catecholamines and locomotor behavior in rats. J Neurochem 34(6):1764–1767. (As cited in ATSDR 2001c.)7381502
Saad AY, Abdelazim AA El-Khashab MM, 1991. Effects of gamma radiation on incisor development of the prenatal albino mouse. J Oral pathol Med 20:385–388. (As cited in ATSDR 2001c.)1941655
Saad AY, Abdelazim AA, El-Khashab MM, 1994. Induction of cleft palate by gamma-irradiation of prenatal CD-1 mice. Cleft Palate Craiofac J 31(5):351–355. (As cited in ATSDR 2001c.)
Szabo B, Patterson E, Scherlag B, 1987. Early after depolarizations induced by Cs^+^ are dependent on intra- and extracellular [Ca^2+^] and [Na^+^]. Circulation 76:IV–115. (As cited in ATSDR 2001c.)