# Appendix B Background Information for Cobalt

Cobalt is a naturally occurring element that exists in the environment as the free metal, and in the (II) and (III) oxidation states. Because the biological availability and toxicity of cobalt are primarily related to the cobalt(II) oxidation state, ATSDR (2001d) has focused on that form of cobalt. While a number of radioisotopes of cobalt exist (see ATSDR 2001d for a more complete discussion), by far the most common is ^60^Co. As such, ATSDR (2001d) has focused primarily on radiation from ^60^Co when discussing radioactive cobalt.

## B.1 Toxicokinetics

The absorption of inhaled cobalt particles from the respiratory tract depends on many factors (ATSDR 2001d). The deposition pattern in the respiratory tract is related to particle size and aerodynamic properties. Fractional deposition of inhaled insoluble cobalt particles in humans varied from approximately 50% for particles with a mean geometric diameter of 0.8 μmole to approximately 75% for particles with a mean diameter of 1.7 μmole (Foster et al. 1989). Fractional deposition can be expected to vary considerably with age and breathing patterns. Once deposited, cobalt particles may be absorbed through the alveoli into the bloodstream, dependent primarily on their solubility, while insoluble particles will be phagocytized by alveolar macrophages. Phagocytized particles will eventually be transported to the stomach (ATSDR 2001d).

Absorption of cobalt compounds following oral exposure varies considerably (ATSDR 2001d), generally on the order of 1–10%, though it may range as high as 34% (Bailey et al. 1989; Collier et al. 1989; Patrick et al. 1989), following oral exposure. More soluble forms of cobalt appear to be more readily absorbed (Kreyling et al. 1986). Administration of cobalt chloride labeled with radioactive cobalt-58 and complexed with histidine, lysine, glycylglycine, ethylenediaminetetraacetic acid (EDTA), casein, or glycine resulted in decreased gastrointestinal absorption of cobalt, whereas administration of cobalt chloride (with cobalt-58 tracer) in cows' milk permitted a significantly greater (about 40%) fractional absorption through the gastrointestinal tract than cobalt chloride alone (Taylor 1962). Iron deficiency led to increased absorption of cobalt from the gastrointestinal tract, relative to iron-sufficient animals, and simultaneous administration of cobalt and iron in iron-deficient animals reduced the amount of cobalt absorbed, relative to cobalt alone (Reuber et al. 1994; Schade et al. 1970). Increasing oral doses of cobalt resulted in decreased fractional absorption (Houk et al. 1946; Kirchgessner et al. 1994; Taylor 1962).

Absorption is 3- to 15-fold greater in younger animals (rats and guinea pigs) than in adult animals (Naylor and Harrison 1995).

Four volunteers who placed their right hands in a box filled with hard metal dust (∼5–15% cobalt metal, 95–85% tungsten carbide) showed an increase in urinary cobalt levels by an order of magnitude in the post-exposure samples, relative to pre-exposure samples (Scansetti et al. 1994). The levels remained elevated for as long as 48–60 hours. The absorption of 2.2×10^−5^ mg ^60^Co/kg as cobalt chloride in 1.4N HCl through the intact or abraded skin of guinea pigs was examined by Inaba and Suzuki-Yasumoto (1979). Absorption through intact skin was very small (<1%), while absorption through abraded skin was almost 80% at 3 hours post-exposure. A study in hamsters (Lacy et al. 1996) also reported a low amount of absorption of cobalt through unabraded skin.

Following inhalation exposure of humans to insoluble cobalt compounds (cobalt metal, cobalt oxides), clearance from the body, assessed by both urinary/fecal clearance as well as a reduction in whole-body retention, appears to follow three-phase kinetics, with half-lives of 2–44 hours, 10–78 days, and on the order of years (ATSDR 2001d). Due to generally poor absorption following oral exposure, much of an oral dose of cobalt will be rapidly excreted in the feces. Absorbed cobalt, regardless of route of exposure, is eliminated primarily in the urine, with a small amount (5–30%) eliminated in the bile and feces. As a general rule, large amounts of absorbed cobalt are not retained within the body for long periods of time.

Following injection, animal studies have shown that the chemical form of the cobalt compound can affect its elimination. Subcutaneous injection of cobalt protoporphyrin in rats, in which the cobalt atom is chelated within the porphyrin ring, resulted in a slower elimination from the body than cobalt chloride, with significant cobalt levels (∼20% of initial injection) still present in the body 14 days after exposure (Rosenberg 1993). Likewise, intramuscular injection of cobalt mesoporphyrin resulted in primarily in fecal excretion, with a high systemic retention (Feng et al. 1998).

## B.2 Health Effects

Stable Cobalt. Results from studies of cobalt-exposed humans and animals indicate that the primary targets for the noncarcinogenic effects of cobalt are the respiratory system, heart, testes, immune system, and hematological effects (ATSDR 2001d). The critical targets are expected to be the respiratory tract for inhalation exposure, the heart for oral exposure, and the skin for dermal exposure.

Studies of humans occupationally exposed to cobalt have reported respiratory effects, at airborne concentrations as low as 7–15 μg cobalt/m^3^; the most sensitive of these appear to be asthma and decreased ventilatory function, with pneumonia and fibrosis occurring at higher levels (Nemery et al. 1992; Shirakawa et al. 1988, 1989). The mechanism behind these changes is not known, but may result from either direct effects of cobalt on the respiratory tissues or from cobalt’s known sensitizing properties, which are believed to result in the asthma-like effects seen from chronic occupational exposure to cobalt. Similar effects were seen in short-term (NTP 1991) and chronic (NTP 1998) studies in rats and mice, with exposed animals showing respiratory tract inflammation, hyper- and metaplasia, and fibrosis.

Beer-cobalt cardiomyopathy was observed in people who heavily consumed beer containing cobalt sulfate as a foam stabilizer (Alexander 1969, 1972; Morin et al. 1971). The beer drinkers ingested an average of 0.04 mg cobalt/kg/day (Morin et al. 1971) to 0.14 mg cobalt/kg/day for a period of years (Alexander 1969, 1972). The cardiomyopathy was characterized by sinus tachycardia, left ventricular failure, cardiogenic shock, diminished myocardial compliance, absence of a myocardial response to exercise or catecholamine, enlarged heart, pericardial effusion, and extensive intracellular changes (changes in the myofibers, mitochondria, glycogen, and lipids). However, that the cardiomyopathy may have also been due to the fact that the beer-drinkers had protein-poor diets and may have had prior cardiac damage from alcohol abuse. Approximately 40–50% of the patients admitted to the hospital with cardiomyopathy died within several years. In a follow-up study, 0–43% of the survivors showed a residual cardiac disability and 23–41% had abnormal electrocardiograms (Alexander 1972).

Dermatitis is a common result of dermal exposure to cobalt in humans (ATSDR 2001d). Using patch tests and intradermal injections, it has been demonstrated that the dermatitis is probably caused by an allergic reaction to cobalt. Contact allergy was reported in 22 of 223 (9.9%) nurses who were tested with a patch test of 1.0% cobalt chloride (Kieć-Świerczyńska and Kręcisz 2000). Exposure levels associated with the development of dermatitis have not been identified.

Exposure to stable cobalt can lead to sensitization. In its most serious form, cobalt-sensitization can result in or exacerbate asthma (Shirakawa et al. 1988, 1989). Dermal sensitization and related cobalt-dermatitis have also been described. The mechanism for cobalt sensitization is not completely understood.

Antibodies to cobalt have been detected in individuals sensitized to cobalt, suggesting that a humoral immune response is a component of the sensitization phenomenon (Bencko et al. 1983; Shirakawa et al. 1988, 1989).

Following both inhalation and oral exposure of animals to cobalt, adverse effects on the testes were observed (degeneration, atrophy, decreased weight) (ATSDR 2001d). An increase in the length of the estrous cycle was also reported in female mice following inhalation exposure (NTP 1991). Because no effects on the reproductive system were found in patients who died as a result of beer-cobalt cardiomyopathy, at lower daily doses than those studied in animals, the significance of the animal results to humans is not clear.

Chronic-duration animal studies have shown that exposure to cobalt may cause cancers of the respiratory tract following inhalation exposure (NTP 1998). Available studies in occupationally-exposed humans have suggested an increase in cobalt-related cancers, but have not shown a definitive association between cobalt inhalation and increased cancer incidence or mortality (ATSDR 2001d). Data on the carcinogenicity of stable cobalt following the oral and dermal exposure routes are not available.

Radioactive Cobalt. Studies from exposed humans and animals indicate that radiation from cobalt isotopes can affect a wide variety of tissues, with greater effects occurring in tissues with greater levels of cellular division, such as the cells of the gastrointestinal tract (ATSDR 2001d). Radioactive cobalt isotopes emit both beta and gamma radiations. Given that beta radiation penetrates only short distances in tissues, while gamma radiation is highly penetrating, the majority of the systemic effects seen following exposure to radiocobalt are believed to be the result of gamma emission. While data on effects in humans internally exposed to low doses of cobalt radiation are scarce, animal studies suggest that the developing organism is the most sensitive target for external exposures of cobalt radiation. In utero exposure to moderately low doses of cobalt radiation (10–100 rad [0.1–1 Gy]) from external sources has resulted in decreased body weight (Devi et al. 1998; Wang et al. 1993; Zhong et al. 1996), organ weight, including brain weight (Devi et al. 1994, 1998; Hamilton et al. 1989) and delayed or abnormal organ development (Bruni et al. 1994; Devi et al. 1994; Zhong et al. 1996). Beagle dogs exposed in utero to 15–88 rad (0.15–0.88 Gy) of radiation from an external cobalt source showed an increased rate of diabetes mellitus (females only), as well as increased death rates from renal disease and neoplasia (Benjamin et al. 1998a, 1998b). Effects on reproductive organs, particularly in males, as well as an increased incidence of cancer are among the other effects noted following exposures to cobalt radiation (ATSDR 2001d). A detailed description of the health effects of ionizing radiation can be found in the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999).

## B.3 Mechanisms of Action

Stable Cobalt. The exact mechanisms by which cobalt exerts its effects on cells are not completely understood. However, a number of potential mechanisms have been identified. One mechanism by which cobalt may exert its effects is through interactions with the immune system. Exposures of humans to cobalt by the inhalation and dermal routes have resulted in sensitization to cobalt (ATSDR 2001d). Exposure to inhaled cobalt chloride aerosols can precipitate an asthmatic attack in sensitized individuals (Shirakawa et al. 1989), suggesting cobalt sensitization as one mechanism by which cobalt-induced asthma may be produced. IgE and IgA antibodies specific to cobalt have been reported in humans (Bencko et al. 1983; Shirakawa et al. 1988, 1989). There is evidence that cobalt sensitivity in humans may to be regulated by T-lymphocytes (Katsarou et al. 1997). A human helper T-lymphocyte cell line specific for cobalt (CoCl_2_) has been established (Löfström and Wigzell 1986). Cobalt may also interact directly with immunological proteins, such as antibodies or Fc receptors, to result in immunosensitization (Cirla 1994). In vitro, cobalt(III) has been shown to reduce the proliferation of both B and T lymphocytes, as well as the release of the cytokines IL-2, IL-6, and IFN-Gamma (Wang et al. 1996). Interrelationships exist between nickel and cobalt sensitization (Bencko et al. 1983; Rystedt and Fisher 1983). In guinea pigs, nickel and cobalt sensitization appear to be interrelated and mutually enhancing (Lammintausta et al. 1985), though cross-reactivity was not reported to occur.

Soluble cobalt has also been shown to alter calcium influx into cells, functioning as a blocker of inorganic calcium channels (Henquin et al. 1983; Moger 1983; Yamatani et al. 1998). This mechanism has been linked to a reduction of steroidogenesis in isolated mouse Leydig cells (Moger 1983). Additionally, soluble cobalt has been shown to alter the inorganic calcium influx in liver cells after exposure to glucagon (Yamatani et al. 1998), and calcium influx into pancreatic β cells (Henquin et al. 1983) and isolated rat islets (Henquin and Lambert 1975). Cobalt may also affect neuromuscular transmission through antagonism with calcium (Weakly 1973).

Cobalt has been shown to have a number of effects on glucose metabolism. Treatment of animals with cobalt results in a depression of serum glucose levels (Eaton and Pommer 1973; Ybarra et al. 1997). In rats made diabetic by pretreatment with streptozotocin, this depression was persistent, whereas it was transient in normal rats (Ybarra et al. 1997). Many of the effects of cobalt on glucose metabolism are thought to result from alterations in the expression of the glut family of glucose transport proteins, a family of facilitative Na+-independent transport proteins thought to mediate non-insulin-dependent transport of glucose. Exposure to soluble cobalt results in increased expression of genes for these proteins, particularly GLUT1, in cells of the liver, kidney cortex, myocardium, skeletal muscle, and cerebrum (Behrooz and Ismail-Beigi 1997; Ybarra et al. 1997). Cobalt also reduces the amount of glucose produced in liver cells following stimulation with glucagon (Eaton and Pommer 1973;Yamatani et al. 1998), as well as reducing insulin release in isolated rat islets (Henquin and Lambert 1975).

Another potentially important mechanism by which cobalt may exert effects is through its effects on heme and heme-containing enzymes. Cobalt is thought to inhibit heme synthesis in vivo by acting on at least two different sites in the biosynthetic pathway: synthesis of 5-aminolevulinate and conversion of 5-aminolevulinate into heme (de Matteis and Gibbs 1977). This inhibitory activity might result in the formation of cobalt protoporphyrin rather than heme (Sinclair et al. 1979). Cobalt treatment also stimulates heme oxidation in many organs, due to the induction of heme oxygenase (for review, see Sunderman 1987). Effects on heme synthesis may potentially affect a wide variety of heme-containing proteins, including monooxygenase enzymes (i.e., cytochrome P450), and catalase (Yasukochi et al. 1974). Conversely, cobalt acts, through a mechanism believed to involve a heme-containing protein, to increase erythropoietin, which stimulates the production of red blood cells (di Giulio et al. 1991; Goldberg et al. 1988). The regulatory mechanisms behind this apparent dichotomy have not been fully elucidated.

Another potential mechanism for cobalt toxicity is through oxidant-based and free radical-based processes. Exposure to soluble cobalt increases indices of oxidative stress, including diminished levels of reduced glutathione, increased levels of oxidized glutathione, and free-radical-induced DNA damage (Lewis et al. 1991; Zhang et al. 1998). Cobalt has been shown to generate oxygen radicals, including superoxide, both in vitro and in vivo (Kadiiska et al. 1989; Kawanishi et al. 1994; Moorhouse et al. 1985). In vivo exposure to cobalt in rats resulted in increased lipid peroxidation in the liver (Sunderman and Zaharia 1988). Exposure to cobalt results in accumulation in cardiac tissues, and is thought to stimulate carotid-body chemoreceptors, mimicking the action of hypoxia (di Giulio et al. 1990, 1991; Hatori et al. 1993; Morelli et al. 1994). Cobalt administration to a neuroblastoma/glioma cell line resulted in an upregulation of opioid delta receptors, through a mechanism similar to that of hypoxia (Mayfield et al. 1994). Exposure to cobalt also elicits effects on a number of genes known to be sensitive to oxidant status, including hypoxia-inducible factor 1, erythropoietin, vascular endothelial growth factor, catalase, and monooxygenase enzymes (ATSDR 2001d).

Several studies have demonstrated that hard metal, a metal alloy with a tungsten carbide and cobalt matrix, is considerably more toxic than either cobalt or tungsten carbide alone. A mechanism by which hard metal may exert its effects has been proposed by a group of Belgian researchers (Lasfargues et al. 1995; Lison 1996; Lison et al. 1995). In this proposed mechanism, tungsten carbide, which is a very good conductor of electrons, facilitates the oxidation of cobalt metal to ionic cobalt (presumably Co^2+^) by transferring electrons from the cobalt atom to molecular oxygen adjacent to the tungsten carbide molecule. The result is an increased solubility of cobalt, relative to cobalt metal alone, and the generation of active oxygen species, both of which have been shown to occur following in vivo exposure to hard metal. The cobalt ions formed may be absorbed into the blood and transported throughout the body, where they may elicit effects by the above mechanisms. In vitro evidence for this mechanism includes the ability of hard metal particles, but neither cobalt nor tungsten carbide alone, to generate oxidant species and cause lipid peroxidation (Lison et al. 1995; Zanetti and Fubini 1997). Hard metal particles have also been shown to increase the levels of inducible nitric oxide synthase (iNOS), a gene responsive to oxidant stress (Rengasamy et al. 1999).

Radioactive Cobalt. Due to the nature of its ionizing radiation, radioactive cobalt can present a health hazard. Highly-penetrating gamma emissions are the major source of damage to tissues and internal organs following exposure to radioactive cobalt isotopes. If radioactive cobalt is internalized, nearby tissues are at highest risk for damage due to the release of beta particles. In either case, exposure to ionizing radiation results in an increased risk of cellular damage. Ionized molecules within irradiated cells may be repaired quickly to prevent further damage. On the other hand, irreparable damage may be imposed on cellular materials, such as DNA, which might ultimately result in either cell death or the formation of cancerous tumors. Very large acute radiation doses can damage or kill enough cells to cause the disruption of organ systems, resulting in acute radiation sickness or even death. Human and animal data indicate that sufficiently high exposures to cobalt radiation can result in adverse effects such as reduced fertility, abnormal development, genotoxicity, pulmonary fibrosis, gastrointestinal atrophy and fibrosis, hematological and lymphoreticular disorders, cancer, and death (ATSDR 2001d). For a more complete discussion of the mechanisms associated with the toxic effects of ionizing radiation, refer to Chapter 5 of the Toxicological Profile for Ionizing Radiation (ATSDR 1999).

## B.4 Health Guidelines

ATSDR (2001d) did not derive acute or intermediate inhalation MRLs for cobalt due to the lack of suitable data.

ATSDR (2001d) derived a chronic-duration inhalation MRL of 1×10^−4^ mg cobalt/m^3^ based on a NOAEL of 0.0053 mg cobalt/m^3^ and a LOAEL of 0.015 mg cobalt/m^3^ for decreased ventilatory function in exposed diamond-polishing workers (Nemery et al. 1992). The NOAEL was adjusted for continuous exposure and divided by an uncertainty factor of 10 (for human variability).

ATSDR (2001d) did not derive acute, intermediate, or chronic oral MRLs for cobalt due to the lack of suitable data.

ATSDR (2001d) did not derive MRLs specific for external exposure to cobalt radiation. The MRLs for external exposure to ionizing radiation derived in the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999) are applicable to cobalt. The acute MRL of 0.004 Sv is based on neurodevelopmental effects in humans irradiated in utero during the atomic bombings of Hiroshima or Nagasaki. The chronic MRL for ionizing radiation is based on the average yearly background dose of ionizing radiation.

The EPA considers all radionuclides to be cancer classification A (known human carcinogen), and has derived carcinogenic slope factors for inhalation, oral, and external exposure to radiocobalt isotopes (EPA 1997). For the most commonly-occurring isotope, ^60^Co, the cancer slope factor for ingestion exposure is 1.89×10^−11^ pCi^−1^.

## B.5 Derivation of Target Organ Toxicity Dose (TTD) Values

As the available data from the sites of concern report that the vast majority of cobalt contamination in these sites consists of radiocobalt, mainly cobalt-60, the TTD values below are based upon radiocobalt and cobalt radiation. TTDs for chronic oral exposure to radiocobalt mixtures were derived for endpoints affected by radiostrontium and one or more of the other chemicals in strontium-cobalt-cesium-trichloroethylene-PCB mixture that is the subject of this Interaction Profile. The relevant endpoints for radiocobalt in this mixture include hematological, immunological, developmental, neurological, and hepatic endpoints. Chronic oral TTDs for these endpoints are derived below, using the methods described in

ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (2001d), and in particular, the oral LSE table.

### Hematological Effects

Data are not available on the levels of radiocobalt required to elicit hematological effects in humans or animals after oral exposure. Available data in humans after external exposure encompass only single-exposure scenarios. Whole-body external exposure of dogs to 0.075 Sv/day (assuming a quality factor of 1 for cobalt gamma rays) for up to 700 days resulted in a transient (lasting ∼250 days) decrease in hematological parameters, with recovery occurring after 250 days. Using a tissue weighting factor of 0.12 for red bone marrow (ICRP 1993), this corresponds to a minimal LOAEL for hematological effects of radiocobalt of 0.009 Sv/day. To this value, an uncertainty factor of 300 (3 for minimal LOAEL, 10 for animal to human extrapolation, and 10 for intrahuman variability) was applied to give a TTD_HEMATO_ of 3×10^−5^ Sv/day.

### Immunological Effects

Seed et al. (1989) reported a marked reduction in granulocytes, monocytes, and lymphocytes in beagle dogs exposed to 1.65 Sv/day over a 150–300 day period. To this LOAEL value, an uncertainty factor of 1,000 (10 for LOAEL, 10 for animal to human extrapolation, and 10 for intrahuman variability) was applied to give a TTD_IMMUNO_ of 2×10^−3^ Sv/day.

### Reproductive Effects

While it is well-known that radiation from cobalt sources can have an effect on the testes, available human and animal data have only examined the effects of acute exposures. In a subchronic study, Searle et al. (1980) exposed female mice to 10 Sv/day of cobalt radiation, and reported a decrease in number of offspring per litter, and an increase in sterility. To this LOAEL value, an uncertainty factor of 1,000 (10 for LOAEL, 10 for animal to human extrapolation, and 10 for intrahuman variability) was applied to give a TTD_REPRO_ of 1×10^−2^ Sv/day.

### Neurological Effects

Available studies with radiocobalt compounds or cobalt radiation suggest that the nervous system is only affected by cobalt radiation at very high (∼5,000 Sv or more) radiation doses, or when exposure occurs during the development of the nervous system in utero (ATSDR 2001d). No TTD was derived.

### Developmental Effects

ATSDR (1999) has derived an acute-duration (14 days or less) MRL of 0.004 Sv for exposure to ionizing radiation, based on neurodevelopmental effects (decreased IQ scores) in humans exposed in utero during the atomic bombing of Hiroshima and Nagasaki. This number is therefore adopted as the TTD for developmental effects of cobalt radiation.

### Hepatic Effects

Available data on cobalt toxicity do not suggest that the liver is not a sensitive target following exposure to radiocobalt compounds. No TTD was derived.

### Summary (TTDs for Radiation from Cobalt)

TTD_HEMATO_ = 3×10^−5^ Sv/day (dose localized to bone marrow)

TTD_IMMUNO_ = 2×10^−3^ Sv/day (total body dose)

TTD_REPRO_ = 1×10^−2^ Sv/day (total body dose)

TTD_DEVELOP_ = 4×10^−3^ Sv (total body dose)

TTD_NEURO_ = Not applicable

TTD_HEPATIC_ = Not applicable

## B.6 References

Alexander CS. 1969. Cobalt and the heart. Ann Intern Med 70:411–413. (As cited in ATSDR 2001b.)5764511
Alexander CS. 1972. Cobalt-beer cardiomyopathy: A clinical and pathological study of twenty-eight cases. Am J Med 53:395–417. (As cited in ATSDR 2001b.)4263183
ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
ATSDR. 2001a. Draft guidance manual for preparation of an interaction profile. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
ATSDR. 2001d. Toxicological profile for cobalt. Atlanta, GA: Agency for Toxic Substances and Disease Registry.
Bailey MR, Kreyling WG, Andre S, 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- Part 1: Objectives and summary of results. J Aerosol Sci 20(2):169–188. (As cited in ATSDR 2001b.)
Behrooz A, Ismail-Beigi F. 1997. Dual control of glut1 glucose transporter gene expression by hypoxia and by inhibition of oxidative phosphorylation. J Biol Chem 272(9):5555–5562. (As cited in ATSDR 2001b.)9038162
Bencko V, Wagner V, Wagnerova M, 1983. Immuno-biochemical findings in groups of individuals occupationally and non-occupationally exposed to emissions containing nickel and cobalt. J Hyg Epidemiol Microbiol Immunol 27(4):387–394. (As cited in ATSDR 2001b.)
Benjamin SA, Lee AC, Angleton GM, 1998a. Mortality in beagles irradiated during prenatal and postnatal development. I. Contribution of non-neoplastic diseases. Radiat Res 150:316–329. (As cited in ATSDR 2001b.)9728661
Benjamin SA, Lee AC, Angleton GM, 1998b. Mortality in beagles irradiated during prenatal and postnatal development. II. Contribution of benign and malignant neoplasia. Radiat Res 150:330–348. (As cited in ATSDR 2001b.)9728662
Bruni JE, Persaud TVN, Froese G, 1994. Effects of in utero exposure to low dose ionizing radiation on development in the rat. Histol Histopath 9:27–33. (As cited in ATSDR 2001b.)
Cirla AM. 1994. Cobalt-related asthma: Clinical and immunological aspects. Sci Total Environ 150:85–94. (As cited in ATSDR 2001b.)7939614
Collier CG, Bailey MR, Hodgson A. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- part V: Lung clearance of inhaled cobalt oxide particles in hamsters, rats and guinea-pigs. J Aerosol Sci 20(2):233–247. (As cited in ATSDR 2001b.)
de Matteis F, Gibbs AH. 1977. Inhibition of haem synthesis caused by cobalt in rat liver. Biochem J 162:213–216. (As cited in ATSDR 2001b.)849279
Devi PU, Baskar R, Hande MP. 1994. Effect of exposure to low-dose gamma radiation during late organogenesis in the mouse fetus. Radiat Res 138:133–138. (As cited in ATSDR 2001b.)8146293
Devi PU, Hossain M, Bisht KS. 1998. Effect of gamma radiation on the foetal haemopoietic system in the mouse. Int J Radiat Biol 74(5):639–646. (As cited in ATSDR 2001b.)9848283
di Giulio C, Data PG, Lahiri S. 1991. Chronic cobalt causes hypertrophy of glomus cells in the rat carotid body. Am J Physiol 261:C102–C105. (As cited in ATSDR 2001b.)1858849
di Guilio C, Huang WX, Lahiri S, 1990. Cobalt stimulates carotid body chemoreceptors. J Appl Physiol 68(5):1844–1849. (As cited in ATSDR 2001b.)2361886
Eaton and Pommer. 1973. Glucagon secretion and activity in the cobalt chloride-treated rat. Amer J Physiol 22567–72. (As cited in ATSDR 2001b.)
EPA. 1997. Health effects assessment summary tables: FY 1997 update. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Emergency and Remedial Response. NTIS PB97–921199. (As cited in ATSDR 2001b.)
Feng MR, Rossi DT, Strenkoski C, 1998. Disposition kinetics of cobalt mesoporphyrin in mouse, rat, monkey and dog. Xenobiotica 28(4):413–426. (As cited in ATSDR 2001b.)9604304
Foster PP, Pearman I, Ramsden D. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- part II: Lung clearance of inhaled cobalt oxide in man. J Aerosol Sci 20(2):189–204. (As cited in ATSDR 2001b.)
Goldberg MA, Dunning SP, Bunn HF. 1988. Regulation of the erythropoietin gene: Evidence that the oxygen sensor is a heme protein. Science 242:1412–1415. (As cited in ATSDR 2001b.)2849206
Hamilton BF, Benjamin SA, Angelton GM, 1989. The effect perinatal ^60^Coγ radiation on brain weight in beagles. Radiat Res 119:366–379. (As cited in ATSDR 2001b.)2667028
Hattori Y, Moriwaki A, Hayashi Y, 1993. Involvement of adenosine-sensitive cyclic AMP-generating systems in cobalt-induced epileptic activity in the rat. J Neurochem 61:2169–2174. (As cited in ATSDR 2001b.)8245969
Henquin J-C, Lambert AE. 1975. Cobalt inhibition of insulin secretion and calcium uptake by isolated rat islets. Am J Physiol 228(6):1669–1677. (As cited in ATSDR 2001b.)1098481
Henquin J-C, Schmeer W, Meissner HP. 1983. Forskolin, an activator of adenylate cyclase, increase Ca2+-dependent electrical activity induced by glucose in mouse pancreatic B cells. Endocrinology 112(6):2218–2220. (As cited in ATSDR 2001b.)6343063
Houk AEH, Thomas AW, Sherman HC. 1946. Some interrelationships of dietary iron, copper and cobalt in metabolism. J Nutr 31:609–620. (As cited in ATSDR 2001b.)20983450
ICRP. 1993. Age dependent doses to members of the public from intake of radionuclides. Part 2: Ingestion dose coefficients. International Commission on Radiological Protection. Oxford: Pergamon Press. ICRP Publication 67, Part 1: Annuals of the ICRP 23(3/4). (As cited in ATSDR 2001c.)
Inaba J, Suzuki-Yasumoto M. 1979. A kinetic study of radionuclide absorption through damaged and undamaged skin of the guinea pig. Health Phys 37(4):592–595. (As cited in ATSDR 2001b.)536221
Kadiiska MB, Maples KR, Mason RP. 1989. A comparison of cobalt(II) and iron(II) hydroxyl and superoxide free radical formation. Arch Biochem Biophys 275(1):98–111. (As cited in ATSDR 2001b.)2554814
Katsarou A, Baxevanis C, Armenaka M, 1997. Study of persistence and loss of patch test reactions to dichromate and cobalt. Contact Dermatitis 36:87–90. (As cited in ATSDR 2001b.)9062743
Kawanishi S, Inoue S, Yamamoto K. 1994. Active oxygen species in DNA damage induced by carcinogenic metal compounds. Environ Health Perspect Suppl 102(3):17–20. (As cited in ATSDR 2001b.)
Kiek-Swierczynska M, Krecisz B. 2000. Occupational skin diseases among the nurses in the region of Lodz. Int J Occup Med Environ Health 13(3):179–184. (As cited in ATSDR 2001b.)11109741
Kirchgessner M, Reuber S, Kreuzer M. 1994. Endogenous excretion and true absorption of cobalt as affected by the oral supply of cobalt. Biol Trace Elem Res 41:175–189. (As cited in ATSDR 2001b.)7946905
Kreyling WG, Ferron GA, Haider B. 1986. Metabolic fate of inhaled Co aerosols in beagle dogs. Health Phys 51(6):773–795. (As cited in ATSDR 2001b.)3781852
Lacy SA, Merritt K, Brown SA, 1996. Distribution of nickel and cobalt following dermal and systematic administration with in vitro and in vivo studies. J Biomed Mater Res 32:279–283. (As cited in ATSDR 2001b.)8884506
Lammintausta K, Pitkanen O-P, Kalimo K, 1985. Interrelationship of nickel and cobalt contact sensitization. Contact Dermatitis 13:148–152. (As cited in ATSDR 2001b.)4053597
Lasfargues G, Lardot C, Delos M, 1995. The delayed lung responses to single and repeated intratracheal administration of pure cobalt and hard metal powder in the rat. Environ Res 69:108–121. (As cited in ATSDR 2001b.)8608770
Lewis CPL, Demedts M, Nemery B. 1991. Indices of oxidative stress in hamster lung following exposure to cobalt(II) ions: In vivo and in vitro studies. Am J Resp Cell Mol Biol 5:163–169. (As cited in ATSDR 2001b.)
Lison D. 1996. Human toxicity of cobalt-containing dust and experimental studies on the mechanism of interstitial lung disease (hard metal disease). Crit Rev Toxicol 26(6):585–616. (As cited in ATSDR 2001b.)8958466
Lison D, Carbonnelle P, Mollo L, 1995. Physicochemical mechanism of the interaction between cobalt metal and carbide particles to generate toxic activated oxygen species. Chem Res Toxicol 8:600–606. (As cited in ATSDR 2001b.)7548741
Lofstrom A, Wigzell H. 1986. Antigen specific human T cell lines for cobalt chloride. Acta Derm Venereol (Stockh) 66:200–206. (As cited in ATSDR 2001b.)2426895
Mayfield KP, Lai J, Porreca F. 1994. Selective upregulation of opioid delta receptors in NG 108–15 cells by treatment with cobalt: Possible hypoxic regulation. Regul Peptides 54(1):183–184. (As cited in ATSDR 2001b.)
Moger WH. 1983. Effects of the calcium-channel blockers cobalt, verapamil, and D600 on leydig cell steroidogenesis. Biol Reprod 28:528–535. (As cited in ATSDR 2001b.)6303461
Moorehouse CP, Halliwell B, Grootveld M, 1985. Cobalt(II) ion as a promoter of hydroxyl radical and possible 'crypto-hydroxyl' radical formation under physiological conditions. Differential effects of hydroxyl radical scavengers. Biochim Biophys Acta 843:261–268. (As cited in ATSDR 2001b.)2998477
Morelli L, Di Giulio C, Iezzi M, 1994. Effect of acute and chronic cobalt administration on carotid body chemoreceptors responses. Sci Total Environ 150:215–216. (As cited in ATSDR 2001b.)7939599
Morin Y, Tetu A, Mercier G. 1971. Cobalt cardiomyopathy: Clinical aspects. Br Heart J 33:175–178. (As cited in ATSDR 2001b.)
Naylor GPL, Harrison JD. 1995. Gastrointestinal iron and cobalt absorption and iron status in young rats and guinea pigs. Human Exp Toxicol 14:949–954. (As cited in ATSDR 2001b.)
Nemery B, Casier P, Roosels D, 1992. Survey of cobalt exposure and respiratory health in diamond polishers. Am Rev Respir Dis 145:610–616. (As cited in ATSDR 2001b.)1312313
NTP. 1991. NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health. National Toxicology Program. NIH Publication No. 91–3124. (As cited in ATSDR 2001b.)
NTP. 1998. NTP report on the toxicity studies of cobalt sulfate heptahydrate in F344/N rats and B6C3F1 mice (inhalation studies). National Institutes of Health. National Toxicology Program. NIH Publication No. 471. (As cited in ATSDR 2001b.)
Patrick G, Batchelor AL, Stirling C. 1989. An interspecies comparison of the lung clearance of inhaled monodisperse cobalt oxide particles- part VI: Lung clearance of inhaled cobalt oxide particles in SPF Fischer rats. J Aerosol Sci 20(2):249–255. (As cited in ATSDR 2001b.)
Rengasamy A, Kommineni C, Jones JA, 1999. Effects of hard metal on nitric oxide pathways and airway reactivity to methacholine in rat lungs. Toxicol Appl Pharmacol 157:178–191. (As cited in ATSDR 2001b.)10373402
Reuber S, Krcuzer M, Kirchgessner M. 1994. Interactions of cobalt and iron in absorption and retention. J Trace Elem Electrolytes Health Dis 8:151–158. (As cited in ATSDR 2001b.)7599505
Rosenberg DW. 1993. Pharmacokinetics of cobalt chloride and cobalt-protoporphyrin. Drug Metab Dispos 21(5):846–849. (As cited in ATSDR 2001b.)7902247
Rystedt I, Fischer T. 1983. Relationship between nickel and cobalt sensitization in hard metal workers. Contact Dermatitis 9:195–200. (As cited in ATSDR 2001b.)6222874
Scansetti G, Botta GC, Spinelli P, 1994. Absorption and excretion of cobalt in the hard metal industry. Sci Total Environ 150:141–144. (As cited in ATSDR 2001b.)7939587
Schade SG, Felsher BF, Bernier GM, 1970. Interrelationship of cobalt and iron absorption. J Lab Clin Med 75:435–441. (As cited in ATSDR 2001b.)4906743
Searle AG, Beechey CV, Green D, 1980. Comparative effects of protracted exposure to ^60^Coγ-radiation and ^239^Puα-radiation on breeding performance in female mice. Int J Radiat Biol 37(2):189–200. (As cited in ATSDR 2001b.)
Seed TM, Carnes BA, Tolle DV, 1989. Blood responses under chronic low daily dose gamma irradiation: 1. Differential preclinical responses of irradiated male dogs in progression to either aplastic anemia or myeloproliferative disease. Leuk Res 13(12):1069–1084. (As cited in ATSDR 2001b.)2615465
Shirakawa T, Kusaka Y, Fujimura N, 1988. The existence of specific antibodies to cobalt in hard metal asthma. Clin Allergy 18:451–460. (As cited in ATSDR 2001b.)3233723
Shirakawa T, Kusaka Y, Fujimura N, 1989. Occupational asthma from cobalt sensitivity in workers exposed to hard metal dust. Chest 95(1):29–37. (As cited in ATSDR 2001b.)2909353
Sinclair P, Gibbs AH, Sinclair JF, 1979. Formation of cobalt protoporphyrin in the liver of rats. Biochem J 178:529–538. (As cited in ATSDR 2001b.)454362
Sunderman FW. 1987. Metal induction of heme oxygenase. Ann NY Acad Sci 514:65–80. (As cited in ATSDR 2001b.)3327438
Sunderman FW and Zaharia O. 1988. Hepatic lipid peroxidation in CoCl_2_ -treated rats, evidenced by elevated concentrations of thiobarbituric acid chromogens. Res Commun Chem Pathol Pharmacol 59(1):69–78. (As cited in ATSDR 2001b.)3353580
Taylor DM. 1962. The absorption of cobalt from the gastro-intestinal tract of the rat. Phys Med Biol 6:445–451. (As cited in ATSDR 2001b.)13919937
Wang H, Chen D, Gao C, 1993. Effects of low level prenatal ^60^Co gamma-irradiation on postnatal growth and behavior in mice. Teratology 48:451–457. (As cited in ATSDR 2001b.)8303614
Wang JY, Tsukayama DT, Wicklund BH, 1996. Inhibition of T and B cell proliferation by titanium, cobalt, and chromium: Role of IL-2 and IL-6. J Biomed Mater Res 32:655–661. (As cited in ATSDR 2001b.)8953156
Weakly JN. 1973. The action of cobalt ions on neuromuscular transmission in the frog. J Physiol 234:597–612. (As cited in ATSDR 2001b.)4357999
Yamatani K, Saito K, Ikezawa Y, 1998. Relative contribution of Ca^2+^-dependent mechanism in glucagon-induced glucose output from the liver. Arch Biochem Biophys 355(2):175–180. (As cited in ATSDR 2001b.)9675024
Yasukochi Y, Nakamura M, Minakami S. 1974. Effect of cobalt on the synthesis and degradation of hepatic catalase in vivo. Biochem J 144:455–464. (As cited in ATSDR 2001b.)4468818
Ybarra J, Behrooz A, Gabriel A, 1997. Glycemia-lowering effect of cobalt chloride in the diabetic rat: Increased GLUT1 mRNA expression. Mol Cell Endocrinol 133:151–160. (As cited in ATSDR 2001b.)9406861
Zanetti G, Fubini B. 1997. Surface interaction between metallic cobalt and tungsten carbide particles as a primary cause of hard metal lung disease. J Mater Chem 7(8):1647–1654. (As cited in ATSDR 2001b.)
Zhang Q, Kusaka Y, Sato K, 1998. Differences in the extent of inflammation caused by intratracheal exposure to three ultrafine metals: Role of free radicals. J Toxicol Environ Health Part A 53:423–438. (As cited in ATSDR 2001b.)
Zhong DZ, Pei C, Xiu-Qin L. 1996. Neurobehavioral study of prenatal exposure to hyperthermia combined with irradiation in mice. Neurotoxicol Teratol 18:(6)703–709. (As cited in ATSDR 2001b.)8947948