# Appendix A Background Information for Strontium

Strontium is a naturally occurring element that exists in the environment mainly as the free metal or in the (II) oxidation state. Because the biological availability and toxicity of strontium are primarily related to the strontium(II) oxidation state, ATSDR (2001e) has focused on that form of strontium. While a number of radioisotopes of strontium exist, the most common are ^89^Sr and ^90^Sr. As such, ATSDR (2001e) has focused primarily on radiation from ^89^Sr and ^90^Sr when discussing radioactive strontium.

## A.1 Toxicokinetics

Following inhalation exposure to strontium compounds, strontium particles are deposited within the respiratory tract based on their aerosol characteristics. Once deposited, absorption is dependent upon the solubility of the compound, with more soluble compounds being readily absorbed (>80% absorption) and less soluble compounds potentially persisting within the lungs (ATSDR 2001e).

Absorption of strontium from the gastrointestinal tract shares a common mechanism with absorption of calcium. Calcium absorption is higher in physiologic states in which there is an increased demand for calcium, such as pregnancy and lactation, suggesting that strontium absorption may also be higher as well. The fractional absorption of ingested strontium has been estimated in healthy human subjects or hospital patients who received an oral dose of strontium chloride (SrCl_2_) or ingested strontium in the diet (ATSDR 2001e). The results of these studies indicate that approximately 20% (range, 11–25%) of ingested strontium is absorbed from the gastrointestinal tract. Available data suggest no differences in oral absorption of strontium between males and females, nor do available human data suggest a difference in absorption between children and adults (ATSDR 2001e). Studies in rats have suggested that very young animals absorb more strontium than adults (ATSDR 2001e).

There is little evidence for systemic toxicity following dermal exposure to strontium compounds, which would suggest that they are not readily absorbed across the skin of humans (ATSDR 2001e). Absorption of strontium through intact human skin was <1% after 6 hours of exposure, while absorption through scratched and abraded skin was 57% over the same time period (Ilyin et al. 1975).

The metabolism of strontium consists of binding interactions with proteins and, based on its similarity to calcium, probably complex formation with various inorganic anions such as carbonate and phosphate, and carboxylic acids such as citrate and lactate (ATSDR 2001e). These types of interactions would be expected for all routes of exposure.

Absorbed strontium is excreted in both urine and feces (ATSDR 2001e). Urine appears to be the major route of excretion, with a urine:fecal ratio of approximately 3:1 in humans. The observation of fecal excretion of radioactive strontium weeks to decades after an oral exposure or over shorter time periods after an intravenous exposure suggests the existence of a mechanism for transfer of absorbed strontium into gastrointestinal tract, either from the bile or directly from the plasma (ATSDR 2001e). Evidence for direct secretion of strontium from the plasma into the intestine is provided by studies in animals. The available information does not address the extent to which biliary excretion may also contribute to fecal excretion of strontium. Strontium may also leave the body in breast milk, saliva, or seminal fluid (ATSDR 2001e).

## A.2 Health Effects

Stable Strontium. At low exposure levels (below 100 mg/kg/day), ingestion of stable strontium poses no harm to organisms with access to adequate calcium, phosphorus, and vitamin D (ATSDR 2001e). At higher exposure levels, especially under conditions of inadequate calcium, phosphorus, and vitamin D, stable strontium will interfere with normal bone development, causing ‘strontium rickets’ of variable severity. Human children and weanling animals are the most susceptible populations for this effect. ‘Strontium rickets’ have been demonstrated in humans (Özgür et al. 1996), and similar results have been found in animal studies (Kshirsagar 1976; Morohashi et al. 1994; Neufeld and Boskey 1994; Reinholt et al. 1985; Storey 1962).

There was one case of anaphylaxis reported in a paramedic who inhaled strontium-containing smoke in an enclosed space (Federman and Sachter 1997). Although other irritants in the smoke may have contributed to the incident, there is supporting evidence that stable strontium can stimulate the release of histamine from mast cells in vitro (ATSDR 2001e).

Radioactive Strontium. Following exposure to radioactive strontium compounds, the most severe noncarcinogenic effects seen are the result of incorporation of radioactive strontium, an emitter of beta radiation, into the skeleton, with subsequent irradiation of surrounding tissues (ATSDR 2001e). The cells of the bone marrow are thus highly affected, with pancytopenia being a common effect of high doses of internally deposited radiostrontium. Exposure to young animals also resulted in skeletal effects including mild trabecular osteopenia, endosteal and periosteal cortical changes (sclerosis and thickening), and mottling or focal osteolytic lesions. Dose-dependent decreases in platelet and erythrocyte counts of 60–90% have been reported in animal studies (ATSDR 2001e). Similarly, the lymphatic tissues are targets of radiostrontium compounds, with profound depletion of lymphocyte numbers seen in exposed animals, as well as impairments in immune function. Radiostrontium compounds can also result in osteonecrosis and abnormal bone development at very high doses (ATSDR 2001e).

Oral treatment of pregnant dams with radioactive strontium compounds appears to have a minimal effect on fetal survival, although one study in rats showed that treatment prior to mating resulted in an increase in fetal mortality (ATSDR 2001e). Studies of exposure to radioactive strontium compounds have not reported increases in developmental effects (ATSDR 2001e).

One study described some delayed effects of external strontium radiation treatment (24–75 Sv over 6–16 months) within patients in one medical practice in Belgrade, Yugoslavia (now Serbia; Bekerus 1970). Eight or 10 years after treatment, about a third of the patients developed delayed reactions to radiation: achromia, excess pigmentation, slight atrophy, and telangiectasis; the author did not specify the exposure levels that resulted in these effects. Acute dermal reactions to radiostrontium have also been described for depilated skin in mice, guinea pigs, and pigs. As a general rule, the progression of symptoms in animals is as follows: after an asymptomatic period, the skin exhibits increasing erythema and pigmentation changes, leading to dry desquamation. Within a few days, exposed skin enters a period of moist desquamation, during which a serum scab forms. Re-growth of the epithelium then commences at the edges of the irradiated field and from surviving hair follicles. Chronic fibrosis as a delayed skin reaction is seen at 3–6 months postirradiation.

Data on the carcinogenic effects of radioactive strontium compounds in humans are limited, and are generally equivocal. However, a large number of studies in animals have shown that exposure to radioactive strontium compounds results in significant increases in cancer incidence and mortality (ATSDR 2001e). Asstrontium localizes in bone, the most prevalent tumors are those of the bone and bone marrow, including osteosarcoma, chrondrosarcoma, lymphosarcoma, hemangiosarcoma, and leukemia. Inhalation exposure of dogs to insoluble radiostrontium particles has resulted in pulmonary tumors, the most common of which was pulmonary hemangiosarcoma (Snipes et al. 1979). External exposure to strontium radiation has been shown to result in skin tumors, including basal- and squamous-cell carcinoma and fibrosarcoma. In all of these studies, the lifetime radiation doses to the animals were high (4,000–30,000 rad [40–300 Gy]), preventing the extrapolation of these effects to lower doses.

## A.3 Mechanisms of Action

The fact that strontium is chemically similar to calcium allows it to exchange for calcium in bone and other cellular compartments that are enriched in calcium (ATSDR 2001e). Many enzymes that are calcium-dependent will function when strontium is substituted, but changes in kinetic parameters may occur. Strontium can interact with secondary cell messenger systems and transporter systems that normally use calcium. Furthermore, synaptic transmission may be variably affected by strontium. Consequently, at high concentrations, differences in the chemical characteristics between strontium and calcium may be the basis for neurotoxic and neuromuscular perturbations associated with stable strontium intoxication.

Variations in the rate of absorption of soluble strontium compounds will affect the severity of their effects. The rate of strontium incorporation into bone may also be influenced by other factors that affect bone mineralization. Some genetic factors include parathyroid hormone receptor, estrogen receptor 1, epidermal growth factor, type I collagen A1, interleukin 1-alpha, and other genes that have not yet been characterized (Audi et al. 1999; Duncan et al. 1999). Persons with chronic kidney failure may be more susceptible to effects of excess strontium because of a reduced ability to excrete strontium (Apostolidis et al. 1998). A study in rats demonstrated that protein deficiency, especially in combination with ethanol consumption, may increase strontium incorporation into bone while reducing fecal and urinary excretion of strontium (Gonzales-Reimers et al. 1999).

Differences in bone physiology suggest that adult rats may have a higher susceptibility to stable or radioactive strontium effects than adult humans. Unlike most mammals (including humans), the epiphyseal growth plate of the long bones of rats never entirely transforms into bone after sexual maturity, so that bone growth continues throughout life (although reduced after the age of 12 months) (Leininger and Riley 1990). Thus, incorporation of strontium into the skeleton is likely to be relatively higher in adult rats compared to other mammals.

Stable Strontium. In animals, excess strontium indirectly suppresses the activation of vitamin D_3_ in the kidney, which severely reduces the expression of calbindin D messenger ribonucleic acid (mRNA) and the translation of calbindin D protein in the duodenum (Armbrecht et al. 1979, 1998; Omdahl and DeLuca 1972). As a result, duodenal absorption of calcium is reduced. The reported inverse correlation between the amount of strontium that is absorbed and the levels of parathyroid hormone (Vezzoli et al. 1998) suggest that changes in parathyroid hormone levels mediate this effect. While there are no data on strontium-binding to the calcium receptor of the parathyroid gland, it is likely that strontium binds in place of calcium, mimicking calcium and thereby suppressing parathyroid hormone levels. A reduction in parathyroid hormone levels will decrease the level of 1-hydroxylase available to activate vitamin D_3_.

In addition to its effect on calcium absorption, excess absorbed strontium adversely affects bone development in several ways, leading to the development of rickets in children and young animals. Strontium binds directly to hydroxyapatite crystals, which may interfere with the normal crystalline structure of bone (Storey 1962). In addition, excess strontium may prevent the normal maturation of chondrocytes in the epiphyseal plates of long bones (Matsumoto 1976). Excess strontium apparently interferes with the mineralization of complexed acidic phospholipids that is thought to help initiate the formation of hydroxyapatite crystals in developing bone (Neufeld and Boskey 1994). As a result, affected bone contains an excess of complexed acidic phospholipid and a significantly lower ash weight. Insufficient mineralization reduces the strength of bones, so that the inability to resist compression from increasing body weight results in bone distortion (bowing).

There was one case of anaphylaxis reported in a paramedic who inhaled strontium-containing smoke in an enclosed space (Federman and Sachter 1997). Although other irritants in the smoke may have contributed to the incident, there is supporting evidence that large concentrations of stable strontium can stimulate the release of histamine from mast cells (ATSDR 2001e). Stable strontium stimulates degranulation in several cell types and it has been suggested that it acts by mimicking the receptor-linked rise in calcium that is the usual trigger for such events (Best et al. 1981).

Radioactive Strontium. The adverse health effects of radiostrontium are related to its sequestration in bone, the high energy of its beta emissions, and, in the case of strontium-90, its long biological retention and radioactive half-life (ATSDR 2001e). There is some evidence that body size or skeletal density may affect the outcome of exposures to radiostrontium. It was suggested that two cows that survived large oral doses of strontium-90 owed their survival to their breed characteristics (Cragle et al. 1969). The massive skeletons of Holsteins have wide bone marrow cavities so that tissue in the center of the bone marrow is not within range of the 1-centimeter (in soft tissues) beta emissions from radiostrontium bound to bone. Conversely, mice and rats are more vulnerable than large animals to radioactive strontium because all bone marrow tissues are within beta particle range. This renders rats and mice less useful than larger mammals as models for human exposure to radioactive strontium (ATSDR 2001e). In addition, adult rats are less satisfactory models than adults of other species because of the persistence of the epiphyseal cartilaginous plate, which will result in the incorporation of larger amounts of radioactive strontium into bone (ATSDR 2001e).

Beta emissions from radiostrontium bound to bone resulted in various bone lesions (trabecular osteoporosis, sclerosis, osteolytic lesions), particularly in animals that were exposed chronically (Book et al. 1982; Clarke et al. 1972; Momeni et al. 1976). In young rats and rabbits exposed orally to strontium-90, necrotic effects on the vasculature of developing bone secondarily disrupted the process of osteogenesis (Casarett et al. 1962; Downie et al. 1959). Disruption in the metaphyseal microvasculature disorganized the transformation of cartilage into bone, so that chondrocytes inappropriately resumed active proliferation.

The severe reduction in hematopoietic tissue results from irradiation of the bone marrow by radiostrontium incorporated into bone. At high exposure levels, thrombocytopenia may lead to platelet loss severe enough to cause hemorrhaging, and the resulting anemia will be exacerbated by destruction of erythropoietic tissue. Impaired immune function results from the genetic damage to lymphocytes.

Radiostrontium is a genotoxic carcinogen. Following exposure in vivo, cytogenetic analysis has revealed aneuploidy, chromosomal breaks, gaps, rings, and exchanges, which are manifestations of irreparable changes in deoxyribonucleic acid (DNA). In dogs, acute inhalation of insoluble strontium-90 particles that lodged in the lungs resulted in chronic radiation exposure to the lungs, leading to pulmonary hemangiomas and carcinomas of pulmonary epithelia (Snipes et al. 1979). Other tissues were subsequently affected as the radioactive particles were cleared from the lungs. Following acute inhalation of soluble ^90^SrCl_2_ aerosols, some dogs developed carcinomas of nasal airway tissues, probably resulting from irradiation of these tissues from the strontium-90 bound to the underlying bone (Gillett et al. 1987). Following oral or inhalation exposures, absorbed strontium-90 was distributed to bone, from which it irradiated the surrounding tissues and induced various kinds of osteosarcomas, as well as malignancies of hematopoietic tissues in bone marrow (ATSDR 2001e).

## A.4 Health Guidelines

ATSDR (2001e) did not derive inhalation MRLs for stable strontium due to lack of suitable data.

ATSDR (2001e) did not derive acute or chronic oral MRLs for stable strontium due to lack of suitable data. An intermediate-duration (15–364 days) oral MRL of 2.0 mg/kg/day has been derived based on the study of Storey (1962), which found a no-observed-adverse-effect level (NOAEL) of 140 mg/kg/day for bone mineralization abnormalities in weanling rats that were exposed to dietary strontium carbonate for 20 days. This NOAEL was adjusted by an uncertainty factor of 30 (10 for extrapolation from animals to humans and 3 for human variability; a 3 was utilized because young animals are thought to represent a sensitive population) and a modifying factor of 3 (for short study duration and limited endpoint examination) to give the MRL of 2.0 mg strontium/kg/day.

ATSDR (2001e) did not derive MRLs for exposure to radioactive strontium by any exposure route. The MRLs for ionization radiation presented in the ATSDR Toxicological Profile for Ionizing Radiation (ATSDR 1999) were not cited as being applicable for exposures to radiostrontium. While no rationale for this was cited in the profile, it is likely because the ionizing radiation MRLs are based on external exposures in humans, which is likely to be a less important route of concern for radioactive strontium compounds.

The EPA considers all radionuclides to be cancer classification A (known human carcinogen), and has derived carcinogenic slope factors for inhalation, oral, and external exposure to radiostrontium isotopes (EPA 1997). For the most commonly-occurring isotope, ^90^Sr, the cancer slope factor for ingestion exposure is 4.09×10^−11^ pCi^−1^.

## A.5 Derivation of Target Organ Toxicity Dose (TTD) Values

TTDs for chronic oral exposure to radiostrontium mixtures were derived for endpoints affected by radiostrontium and one or more of the other chemicals in strontium-cobalt-cesium-trichloroethylene-PCB mixture that is the subject of this Interaction Profile. The relevant endpoints for radiostrontium in this mixture include hematological and immunological endpoints. Chronic oral TTDs for these endpoints are derived below, using the methods described in ATSDR (2001a, Section 2.3.2). The derivations are based on data provided in ATSDR (2001e), and in particular, the oral levels of significant exposure (LSE) table.

### Hematological Effects

Exposed persons from the Techa River population (see Section 2.2.2 of this document) exhibited alterations in hematological parameters, including thrombocytopenia (Akleyev et al. 1995). These effects were observed in a portion of the exposed population that received radiation doses to the bone marrow at rates in excess of 30–50 rem (0.3–0.5 Sv) per year. While this population received co-exposure to cesium as well, the bulk of the radiation dose to the affected tissue (bone marrow progenitor cells) is believed to be related to internalized radiostrontium. The 0.3 Sv/year level, utilized as a lowest-observed-adverse-effect-level (LOAEL), converted to 8×10^−4^ Sv/day, and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for intrahuman variability) was used to derive a TTD_HEMATO_ of 8×10^−6^ Sv/day.

### Immunological Effects

Exposed persons from the Techa River population (see Section 2.2.2 of this document) exhibited alterations in immunological parameters, including leukopenia and granulocytopenia (Akleyev et al. 1995). These effects were observed in a portion of the exposed population that received radiation doses to the bone marrow at rates in excess of 30–50 rem (0.3–0.5 Sv) per year. While this population received co-exposure to cesium as well, the bulk of the radiation dose to the affected tissue (bone marrow progenitor cells) is believed to be related to internalized radiostrontium. The 0.3 Sv/year level (utilized as a LOAEL), converted to 8×10^−4^ Sv/day, and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for intrahuman variability) was used to derive a TTD_HEMATO_ of 8×10^−6^ Sv/day.

### Reproductive Effects

Available data on strontium toxicity do not suggest that exposure to radiostrontium compounds results in effects on the testes. No TTD was derived.

### Neurological Effects

Available data on strontium toxicity do not suggest that exposure to radiostrontium compounds results in neurological effects. No TTD was derived.

### Developmental Effects

Available data on strontium toxicity do not suggest that exposure to radiostrontium compounds results in developmental effects. No TTD was derived.

### Hepatic Effects

Available data on strontium toxicity do not suggest that exposure to radiostrontium compounds results in effects on the liver. No TTD was derived.

### Summary (TTDs for Radiostrontium)

TTD_HEMATO_ = 8×10^−6^ Sv/day (radiation dose localized to bone marrow)

TTD_IMMUNO_ = 8×10^−6^ Sv/day (radiation dose localized to bone marrow)

TTD_REPRO_ = Not applicable

TTD_DEVELOP_ = Not applicable

TTD_NEURO_ = Not applicable

TTD_HEPATIC_ = Not applicable

## A.6 References

Akleyev AV, Kossenko MM, Silkina LA, 1995. Health effects of radiation incidents in the Southern Urals. Stem Cells 13(Suppl 1):58–68. (As cited in ATSDR 2001a.)7488969
Apostolidis N, Paradellis T, Karydas A, 1998. Calcium and strontium metabolic studies in patients on CAPD. Perit Dial Int 18(4):410–414. (As cited in ATSDR 2001a.)10505563
Armbrecht HJ, Boltz MA, Christakos S, 1998. Capacity of 1,25-Dihydroxyvitamin D to stimulate expression of calbindin D changes with age in the rat. Arch Biochem Biophys 352(2):159–164. (As cited in ATSDR 2001a.)9587402
Armbrecht HJ, Wasserman RH, Bruns MEH. 1979. Effect of 1,25-dihydroxyvitamin D_3_ on intestinal calcium absorption in strontium-fed rats. Arch Biochem Biophys 192(2):466–473. (As cited in ATSDR 2001a.)107861
ATSDR. 1999. Toxicological profile for ionizing radiation. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
ATSDR. 2001a. Draft guidance manual for the assessment of joint toxic action of chemical mixtures. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
ATSDR. 2001e. Toxicological profile for strontium. Atlanta, GA: Agency for Toxic Substances and Disease Registry. U.S. Department of Health and Human Services. Public Health Service.
Audi L, Garcia-Ramirez M, Carrascosa A. 1999. Genetic determinants of bone mass [Abstract]. Horm Res 51(3):105–123. (As cited in ATSDR 2001a.)10461016
Bekerus M. 1970. [Late reaction following radiation with Sr^90^-derma plates, followed up for 8 and more years]. Strahlentherapie 140(1):105–107. (German). (As cited in ATSDR 2001a.)5486784
Best LC, Bone EA, Russell RGG. 1981. Strontium ions induce production of thromboxane B_2_ and secretion of 5-hydroxytryptamine in washed human platelets. Biochem Pharmacol 30:635–637. (As cited in ATSDR 2001a.)6268118
Book SA, Spangler WL, Swartz LA. 1982. Effects of lifetime ingestion of ^90^Sr in beagle dogs. Radiat Res 90:244–251. (As cited in ATSDR 2001a.)7079461
Casarett GW, Tuttle LW, Baxter RC. 1962. Pathology of imbibed Sr^90^ in rats and monkeys. In: Dougherty TF, Jee WSS, Mays CW, , ed. Some aspects of internal irradiation: Proceedings of a symposium held at the Homestead, Heber, Utah 8–11 May 1961. New York, NY: Pergamon Press, 329–336. (As cited in ATSDR 2001a.)
Clarke WJ, Busch RH, Hackett PL, 1972. Strontium-90 effects in swine: A summary to date. AEC Symp Ser 25:242–258. (As cited in ATSDR 2001a.)
Cragle RG, Stone WH, Bacon JA, 1969. Effects of large doses of orally ingested strontium-90 on young cattle. Radiat Res 37:415–422. (As cited in ATSDR 2001a.)5765550
Downie ED, Macpherson S, Ramsden EN, 1959. The effect of daily feeding of ^90^Sr to rabbits. Br J Cancer 13:408–423. (As cited in ATSDR 2001a.)13817911
Duncan EL, Brown MA, Sinsheimer J, 1999. Suggestive linkage of the parathyroid receptor type 1 to osteoporosis [Abstract]. J Bone Miner Res 14(12):2000–2001. (As cited in ATSDR 2001a.)10620057
EPA. 1997. Health effects assessment summary tables: FY 1997 update. Washington, DC: U.S. Environmental Protection Agency, Office of Research and Development, Office of Emergency and Remedial Response. NTIS PB97–921199. (As cited in ATSDR 2001a.)
Federman JH, Sachter JJ. 1997. Status asthmaticus in a paramedic following exposure to a roadside flare: A case report. J Emerg Med 15(1):87–89. (As cited in ATSDR 2001a.)9017492
Gillett NA, Muggenburg BA, Boecker BB, 1987. Single inhalation exposure to ^90^SrCl_2_ in the beagle dog: Late biological effects. J Natl Cancer Inst 79:359–376. (As cited in ATSDR 2001a.)3110478
Gonzalez-Reimers E, Rodriguez-Moreno F, Martinez-Riera A, 1999. Relative and combined effects of ethanol and protein deficiency on strontium and barium bone content and fecal and urinary excretion. Biol Trace Elem Res 68:41–49. (As cited in ATSDR 2001a.)10208655
Ilyin LA, Ivannikov AT, Parfenov YD, 1975. Strontium absorption through damaged and undamaged human skin. Health Phys 29:75–80. (As cited in ATSDR 2001a.)807536
Kshirsagar SG. 1975. The effect of stable strontium on the alkaline phosphatase activity of rat tissues -- In vitro studies. Biochem Pharmacol 24:13–20. (As cited in ATSDR 2001a.)1122253
Leininger JR, Riley MGI. 1990. Bones, joints, and synovia. In: Boorman GA, Eustis SL, Elwell MR, eds. Pathology of the fischer rat: Reference and atlas. New York, NY: Academic Press, Inc. 209–226. (As cited in ATSDR 2001a.)
Matsumoto A. 1976. Effect of strontium on the epiphyseal cartilage plate of rat tibiae -- Histological and radiographic studies. Jpn J Pharmacol 26:675–681. (As cited in ATSDR 2001a.)1021603
Momeni MH, Williams JR, Jow N, 1976. Dose rates, dose and time effects of ^90^Sr + ^90^Y and ^226^Ra on beagle skeleton. Health Phys 30:381–390. (As cited in ATSDR 2001a.)1270266
Morohashi T, Sano T, Yamada S. 1994. Effects of strontium on calcium metabolism in rats: I. A distinction between the pharmacological and toxic doses. Jpn J Pharmacol 64:155–162. (As cited in ATSDR 2001a.)8022117
Neufeld EB, Boskey AL. 1994. Strontium alters the complexed acidic phospholipid content of mineralizing tissues. Bone 15(4):425–430. (As cited in ATSDR 2001a.)7917582
Omdahl JL, DeLuca HF. 1972. Rachitogenic activity of dietary strontium. J Biol Chem 247(17):5520–5526. (As cited in ATSDR 2001a.)4341346
Özgür S, Sümner H, Kocoglu G. 1996. Rickets and soil strontium. Arch Dis Child 75:524–526. (As cited in ATSDR 2001a.)9014608
Reinholt FP, Engfeldt B, Heinegard D, 1985. Proteoglycans and glycosaminoglycans of normal and strontium rachitic epiphyseal cartilage. Coll Relat Res 5:41–53. (As cited in ATSDR 2001a.)3919994
Snipes MB, Hahn FF, Muggenburg BA, 1979. Toxicity of ^90^Sr inhaled in a relatively insoluble form by beagle dogs, X. In: Inhalation Toxicology Research Institute, ed. Annual reports of the Inhalation Toxicology Research Institute. Albuquerque, NM: Inhalation Toxicology Research Institute, 101–106. (As cited in ATSDR 2001a.)
Storey E. 1962. Strontium "rickets": Bone, calcium and strontium changes. Australia Ann Med 10:213–222. (As cited in ATSDR 2001a.)
Vezzoli G, Baragetti I, Zerbi S, 1998. Strontium absorption and excretion in normoclaciuric subjects: Relation to calcium metabolism. Clin Chem 44(3):586–590. (As cited in ATSDR 2001a.)9510866