# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

Ah: aryl hydrocarbon
ALI: annual limit on intake
ARS: acute radiation sickness
ATSDR: Agency for Toxic Substances and Disease Registry
BINWOE: binary weight-of-evidence
Bq: Becquerel
CDDs: chlorinated dibenzo-p-dioxins
CDFs: chlorinated dibenzofurans
CERCLA: Comprehensive Environmental Response, Compensation, and Recovery Act
Ci: Curie
Co: cobalt
CoCl_2_: cobalt chloride
CRS: chronic radiation sickness
Cs: cesium
DCVC: S-( 1,2-dichlorovinyl)-L-cysteine
DCVG: S-( 1,2-dichlorovinyl)glutathione
DNA: deoxyribonucleic acid
DOE: Department of Energy
DT: Division of Toxicology
EADs: early afterdepolarizations
EDTA: ethylenediaminetetraacetic acid
ED_50_: median effective dose (produces measured effect in 50% of population)
EPA: Environmental Protection Agency
EROD: ethoxyresourufin-O-deethylase
Gy: Gray
IARC: International Agency for Research on Cancer
ICRP: International Commission on Radiological Protection
INEEL: Idaho National Environmental and Engineering Laboratory
iNOS: inducible nitric oxide synthase
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LOAEL: lowest-observed-adverse-effect level
LSE: levels of significant exposure
mg: milligram
mL: milliliter
MRL: Minimal Risk Level
mRNA: messenger ribonucleic acid
mSv: millisievert
NCRP: National Council on Radiation Protection and Measurements
NOAEL: no-observed-adverse-effect level
NRC: Nuclear Regulatory Commission
NTP: National Toxicology Program
PBPK: physiologically based pharmacokinetic
PBPK/PD: physiologically-based pharmacokinetic/pharmacodynamic
PCBs: polychlorinated biphenyls
PFC: plaque-forming cell
ppb: parts per billion
ppm: parts per million
ppt: parts per trillion
PTU: 6-propyl-2-thiouracil
RfC: reference concentration
RfD: reference dose
SGOT: serum glutamic-oxaloacetic transaminase
Sr: strontium
SrCl_2_: strontium chloride
SRBC: sheep red blood cells
Sv: Sievert
TCDD: 2,3,7,8-tetrachlorodibenzo-p-dioxin
TCE: trichloroethylene
TEF: toxicity equivalent factor
TEQ: toxic equivalency
TSH: thyroid stimulating hormone
TTD: target-organ toxicity dose
UDP-GT: uridine-5'-diphosphate glucuronyltransferases
μg: microgram
μmole: micromole
U.S.: United States
VOC: volatile organic compound
VT: ventricular tachyrhythmia
WOE: weight-of-evidence
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to