# 5 List of References

* Cited in text

*ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
*Andersson K, Fuxe K, Nilsen OG, 1981. Production of discrete changes in dopamine and noradrenaline levels and turnover in various parts of the rat brain following exposure to xylene, ortho-, meta-, and para-xylene, and methylbenzene. Toxicol Appl Pharmacol 60:535–548.7292492
*Andrews LS, Lee EW, Wither CM, 1977. Effects of toluene on the metabolism, disposition and hemopoietic toxicity of [^3^H]benzene. Biochem Pharmacol 26:293–300.849319
Angerer J, Lehnert G. 1979. Occupational chronic exposure to organic solvents. Int Arch Occup Environ Health 43:145–150.437902
Angerer J, Wulf H. 1985. Occupational chronic exposure to organic solvents. Int Arch Occup Environ Health 56:307–321.4066054
Askergren A. 1981. Studies on kidney function in subjects exposed to organic solvents. Acta Med Scand 210:103–106.7293819
Astrand I, Engstrom J, Ovrum P. 1978. Exposure of xylene and methylbenzene. I. Uptake, distribution and elimination in man. Scand J Work Environ Health 4:185–194.705285
*ATSDR. 1992. Public health assessment guidance manual. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1995. Toxicological profile for xylenes. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1997. Toxicological profile for benzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1999a. Toxicological profile for total petroleum hydrocarbons (TPHs). Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 1999b. Toxicological profile for ethylbenzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2000. Toxicological profile for toluene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
*ATSDR. 2001a. Draft guidance manual for the assessment of joint toxic action of chemical mixtures: August, 1999. Atlanta, GA: Agency for Toxic Substances and Disease Registry, Public Health Service, U.S. Department of Health and Human Services.
*ATSDR. 2001b. Draft guidance for the preparation of an interaction profile: August, 1999. Atlanta, GA: Agency for toxic substances and disease registry, Public Health Service, U.S. Department of Health and Human Services.
Au WW, Ward JB, Ramanujam VMS, 1988. Genotoxic effects of a sub-acute low-level inhalation exposure to a mixture of carcinogenic chemicals. Mutat Res 203:103–115.3352641
*Balster RL. 1998. Neural basis of inhalant abuse. Drug Alcohol Depend 51:207–214.9716942
Bond JA, Medinsky MA. 1995. Health risk assessment of chemical mixtures from a research perspective. Toxicol Lett 82/83:521–525.8597104
Bond JA, Leavens TL, Seaton MJ, 1997. Predicting the toxicity of chemical mixtures based on knowledge of individual components. CIIT Act 17(12):1–12.
Bond JA, Leavens TL, Seaton MJ, 1998. Predicting the toxicity of chemical mixtures. Chemtech July:16–23.
*Brondeau MT, Ducos P, Gaudin R, 1992. Evaluation of the interaction of benzene and toluene on the urinary excretion of t,t-muconic acid in rats. Toxicol Lett 61:311–316.1641876
Brown-Woodman PD, Webster WS, Huq F, 1992. Assessment of interactive effects of the aromatic hydrocarbons toluene, xylene and benzene on rat embryonic development in vitro. Teratology 45(3):326.
*Brown-Woodman PDC, Webster WS, Picker K, 1994. In vitro assessment of individual and interactive effects of aromatic hydrocarbons on embryonic development of the rat. Reprod Toxicol 8:121–135.8032123
Caprino L, Togna GI. 1998. Potential health effects of gasoline and its constituents: A review of current literature (1990–1997) on toxicological data. Environ Health Perspect 106:115–125.9452413
Chapman DE, Moore TJ, Michener SR, 1990. Metabolism and covalent binding of 14 C toluene by human and rat liver microsomal fractions and liver slices. Drug Metab Dispos 18:929–936.1981539
Chen C-Y, Chiou Y-S. 1995. Toxicity of binary mixtures of organic chemicals. Environ Toxicol Water Qual 10:97–106.
Chen JD, Wang JD, Jang JP, 1991. Exposure to mixtures of solvents among paint workers and biochemical alterations of liver function. Br J Ind Med 48:696–701.1931729
Chen JD, Wang JD, Tsai SY, 1997. Effects of occupational and nonoccupational factors on liver function tests in workers exposed to solvent mixtures. Arch Environ Health 52(4):270–274.9210726
Chen Z, Liu SJ, Cai SX, 1994. Exposure of workers to a mixture of toluene and xylenes. II. Effects. Occup Environ Med 51:47–49.8124463
*Cruz SL, Mirshahi T, Thomas B, 1998. Effects of the abused solvent toluene on recombinant N-methyl-D-aspartate and non-N-methyl-D-aspartate receptors expressed in Xenopus oocytes. J Pharmacol Exp Ther 286(1):334–340.9655877
Dean BJ. 1985. Recent findings on the genetic toxicology of benzene, toluene, xylenes and phenols. Mutat Res 154:153–181.3930957
Dobrokhotov VB, Yenikeyev MI. 1977. The mutagenic action of benzene, toluene in a mixture of these hydrocarbons in a chronic experiment. Gig Sanit 2(1):32–34.
*Dudek B, Gralewicz K, Jakuboski M, 1990. Neurobehavioral effects of experimental exposure to toluene, xylene and their mixture. Pol J Occup Med 3(1):109–116.2132931
Eastmond DA, Smith MT, Irons RD. 1987. An interaction of benzene metabolites reproduces the myelotoxicity observed with benzene exposure. Toxicol Appl Pharmacol 91:85–95.2823417
El-Masri H, Constan AA, Ramsdell HS, 1996a. Physiologically based pharmacodynamic modeling of an interaction threshold between trichloroethylene and 1,1-dichloroethylene in Fischer 344 rats. Toxicol Appl Pharmacol 141:124–132.8917684
El-Masri H, Tessari JD, Yang RSH. 1996b. Exploration of an interaction threshold for the joint toxicity of trichloroethylene and 1,1-dichloroethylene: utilization of a PBPK model. Arch Toxicol 70:527–539.8831903
*Elovaara E, Engström K, Vaino H. 1982. Unaltered metabolism of m-xylene in the presence of methylbenzene. In: Laitinen M, Hanninen O, eds. Cytochrome P 450 biochemistry, biophysics, and environmental implications. New York: Elsavier Biomedical Press,765–768.
*Elovaara E, Ingstrom K, Vainio H. 1984. Metabolism and disposition of simultaneously inhaled m-xylene and methylbenzene in the rat. Toxicol Appl Pharmacol 75:466–478.6474474
*Engelke M, Tähti H, Vaalavirta L. 1996. Perturbation of artificial and biological membranes by organic compounds of aliphatic, alicyclic and aromatic structure. Toxicol in Vitro 10:111–115.20650189
Engstrom J, Bjurstrom R. 1978. Exposure to xylene and methylbenzene. Scand J Work Environ Health 4:195–203.705286
*Engström K, Riihimäki V, Laine A. 1984. Urinary disposition of methylbenzene and —xylene in man following separate and combined exposure. Int Arch Occup Environ Health 54:355–363.6511105
Farris GM, Wong VA, Wong BA, 1996. Benzene-induced micronuclei in erythrocytes: An inhalation concentration-response study in B6C3F1 mice. Mutagenesis 11(5):455–462.8921506
*Franks NP, Lieb WR. 1985. Mapping of general anaesthetic target sites provides a molecular basis for cutoff effects. Nature 316:349–351.4022125
*Franks NP, Lieb WR. 1987. Anaesthetics on the mind. Nature 328:113–114.3600786
*Frantik E, Vodickova L. 1995. Combined effects of binary solvent mixtures. Cent Eur J Occup Environ Med 1(1):31–37.
*Frantík E, Horváth M, Vodicková L. 1988. [Effects of solvent mixtures on behaviour and seizure characteristics at the utmost additive]. Act Nerv Super (Praha) 30:260–264. (Russian).3227760
Freundt KJ, Schneider J-C. 1986. Drastic increase of the m-xylene or toluene concentrations in blood of rats after combined inhalation with acetone. Naunyn-Schmiedebergs Arch Pharmacol 332(Suppl):104.
*Gad-El-Karim MM, Harper BL, Legator MS. 1984. Modifications in the myeloclastogenic effect of benzene in mice with toluene, phenobarbital, 3-methylcholanthrene, Aroclor 1254 and SKF-525A. Mutat Res 135:225–243.6424008
Gerner-Smidt P, Friedrich U. 1978. The mutagenic effect of benzene, toluene, and xylene studied by the SCE technique. Mutat Res 58:313–316.370577
Gradiski D, Bonnet P, Duprat P, 1981. Etude toxicologique chronique par inhalation chez le rat de l'association benzene-toluene. Toxicol Eur Res 3:201–206.7302947
Gromadzinska J, Wasowicz W, Sklodowska M, 1996. The influence of atmospheric chromium on selenium content and glutathione peroxidase activity in blood of tannery workers. Environ Health Perspect 104(12):1312–1316.9118872
*Gut I, Kopecky J, Nerudova J, 1980. Metabolic and toxic interactions of benzene and acrylonitrile with organic solvents. In: Gut I, Microslav C, Plaa G, eds. Ind Environ Xenobiotics. Prague, Czechoslovakia. Proc Int Conf, 255–262.
Haddad S, Krishnan K. 1998. Physiological modeling of toxicokinetic interactions: Implications for mixture risk assessment. Environ Health Perspect 106(6):1377–1384.9860896
*Haddad S, Béliveau M, Tardif R, 2001. A PBPK modeling-based approach to account for interactions in the health risk assessment of chemical mixtures. Toxicol Sci 63:125–131.11509752
*Haddad S, Charest-Tardif G, Tardif R, 2000. Validation of a physiological modeling framework for simulating the toxicokinetics of chemicals in mixtures. Toxicol Appl Pharmacol 167:199–209.10986011
*Haddad S, Tardif R, Charest-Tardif G, 1999a. Physiological modeling of the toxicokinetic interactions in a quaternary mixture of aromatic hydrocarbons. Toxicol Appl Pharmacol 161:249–257.10620482
*Haddad S, Tardif R, Viau C, 1999b. A modeling approach to account for toxicokinetic interactions in the calculation of biological hazard index for chemical mixtures. Toxicol Lett 108:303–308.10511275
Haglund U, Lundberg I, Zech L. 1980. Chromosome aberrations and sister chromatid exchanges in Swedish paint industry workers. Scand J Work Environ Health 6:291–298.7233117
Hansen H, De Rosa CT, Pohl H, 1998. Public health challenges posed by chemical mixtures. Environ Health Perspect 106(Suppl. 6):1271–1280.9860881
Hristeva-Mirtcheva V. 1998. Changes in the peripheral blood of workers with occupational exposure to aromatic hydrocarbons. Int Arch Occup Environ Health 71(Suppl):S81–S83.9827888
*Hsieh GC, Parker RDR, Sharma R, 1990a. Subclinical effects of groundwater contaminants. III. Effects of repeated oral exposure to combinations of benzene and toluene on immunologic responses in mice. Arch Toxicol 64:320–328.2143647
*Hsieh GC, Sharma RP, Parker RDR. 1990b. Subclinical effects of groundwater contaminants. IV. Effects of repeated oral exposure to combinations of benzene and toluene on regional brain monoamine metabolism in mice. Arch Toxicol 64:669–676.2090036
*Huang MY, Jin C, Liu YT, 1994. Exposure of workers to a mixture of toluene and xylenes. I. Metabolism. Occup Environ Med 51:42–46.8124462
*IARC. 1987. Benzene Group 1: A. Evidence for carcinogenicity to humans (sufficient). In: IARC Monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC Monographs Volumes 1 to 42. Lyon, France: World Health Organization, International Agency for Research on Cancer.
*IARC. 1999a. Monographs on the evaluation of carcinogenic risks to humans. Toluene. In: Volume 71 Part Two. Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide. Lyon, France: World Health Organization, 829–864.
*IARC. 1999b. Monographs on the evaluation of carcinogenic risks to humans. Xylenes. In: Volume 71 Part Three. Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide. Lyon, France: World Health Organization, 1189–1208.
*IARC. 2000. Some industrial chemicals. Ethylbenzene. Volume 77. In: IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: World Health Organization, International Agency for Research on Cancer, 227–266.
Ikeda M. 1988. Multiple exposure to chemicals. Regul Toxicol Pharmacol 8:414–421.3222483
Ikeda M. 1995. Exposure to complex mixtures: Implications for biological monitoring. Toxicol Lett 77:85–91.7618172
*Ikeda M, Ohtsuji H, Imamura T. 1972. In vivo suppression of benzene and styrene oxidation by co-administered toluene in rats and effects of phenobarbital. Xenobiotica 2(2):101–106.5056809
Inoue O, Seiji K, Kawai T, 1993. Excretion of methylhippuric acids in urine of workers exposed to a xylene mixture: Comparison among three xylene isomers and toluene. Int Arch Occup Environ Health 64:533–539.8482596
*Inoue O, Seiji K, Nakatsuka H, 1989a. Excretion of 1,2,4-benzenetriol in the urine of workers exposed to benzene. Br J Ind Med 46:559–565.2775675
Inoue O, Seiji K, Nakatsuka H, 1989b. Urinary t,t-muconic acid as an indicator of exposure to benzene. Br J Ind Med 46:122–127.2923822
*Inoue O, Seiji K, Watanabe T, 1988. Mutual metabolic suppression between benzene and toluene in man. Int Arch Occup Environ Health 60:15–20.3350599
*IRIS. 2001. Benzene, Toluene, Ethylbenzene, and Xylenes. Integrated Risk Information System, U.S. Environmental Protection Agency. http//:www.epa.gov/iris/subst/index.html (http://www.epa.gov/iris/subst/index.html).
*Jakubowski M, Kostrzewski P. 1989. [Excretion of methylbenzoic acid in urine as a result of single and combined exposure to m-xylene.] Pol J Occup Med 2(3):238–247. (Polish)2489427
Johnson A-C, Nylen PR. 1995. Effects of industrial solvents on hearing. Occup Med State Art Rev 10(3):623–640.
Kawai T, Mizunuma K, Yasugi T, 1991. Urinary methylhippuric acid isomer levels after occupational exposure to a xylene mixture. Int Arch Occup Environ Health 63:69–75.1856026
Kawai T, Yasugi T, Mizunuma K, 1992. Comparative evaluation of urinalysis and blood analysis as means of detecting exposure to organic solvents at low concentrations. Int Arch Occup Environ Health 64:223–234.1468790
Kononen DW, Gorski RA. 1997. A method for evaluating the toxicity of industrial solvent mixtures. Environ Toxicol Chem 16(5):968–976.
Korn M, GfrÖrer W, Herz R, 1992. Stereometabolism of ethylbenzene in man: Gas chromatographic determination of urinary excreted mandelic aid enentiomers and phenylglyoxylic acid and their relation to the height of occupational exposure. Int Arch Occup Environ Health 64:75–78.1399026
*Korsak Z, Sokal J, Dedyk A, 1988. Toxic effects of combined exposure to toluene and xylene in animals. I. Acute inhalation study. Pol J Occup Med 1(1):45–50.2980149
*Korsak Z, Sokal JA, Górny R. 1992. Toxic effects of combined exposure to toluene and m-xylene in animals. III. Subchronic inhalation study. Pol J Occup Med Environ Health 5(1):27–33.1392650
Korsak Z, Sokal JA, Swiercz R. 1991. The toxic effects of combined exposure to toluene and m-xylene in animals. II. Blood toluene and m-xylene during single and combined exposure in rats. Pol J Occup Med Environ Health 4(4):377–382.1817685
Krishnan K, Pelekis M. 1995. Hematotoxic interactions: Occurrence, mechanisms and predictability. Toxicology 105:355–364.8571372
Krishnan K, Andersen ME, Clewell HJ III, 1994. Physiologically based pharmacokinetic modeling of chemical mixtures. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, 399–437.
Kumagai S, Matsunaga I. 1992. Fluctuations of occupational exposure indices to mixtures. Ann Occup Hyg 36(2):131–143.1530230
Kumagai S, Matsunaga I. 1995a. Changes in the distribution of short-term exposure concentration with different averaging times. Am Ind Hyg Assoc J 56(1):24–31.7872201
Kumagai S, Matsunaga I. 1995b. Models describing variation of short-term exposure levels of two chemicals. Ann Occup Hyg 39(1):7–20.
*Lange A, Smolik R, Zatonki W, 1973. Serum immunoglobulin levels in workers exposed to benzene, toluene and xylene. Int Arch Arbeitsmed 31:37–44.4692814
Lapare S, Tardif R, Brodeur J. 1993. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air. Int Arch Occup Environ Health 64:569–580.8314616
Lemasters GK, Lockey JE, Olsen DM, 1999. Comparison of internal dose measures of solvents in breath, blood, and urine and genotoxic changes in aircraft maintenance personnel. Drug Chem Toxicol 22(1):181–200.10189578
Liu Y, Fechter LD. 1997. Toluene disrupts outer hair cell morphometry and intracellular calcium homeostasis in cochlear cells of guinea pigs. Toxicol Appl Pharmacol 142:270–277.9070349
Maizlish NA, Langolf GD, Whitehead LW, 1985. Behavioural evaluation of workers exposed to mixtures of organic solvents. Br J Ind Med 42:579–590.3876109
Marks TA, Ledoux TA. 1982. Teratogenicity of a commercial xylene mixture in the mouse. J Toxicol Environ Health 9:97–105.7062354
Medinsky MA, Schlosser PM, Bond JA. 1994. Critical issues in benzene toxicity and metabolism: The effect of interactions with other organic chemicals on risk assessment. Environ Health Perspect 102(9):119–124.
*Mergler D, Beauvais B. 1992. Olfactory threshold shift following controlled 7-hour exposure to toluene and/or xylene. Neurotoxicology 13:211–216.1508422
*Mihic SJ, McQuilkin SJ, Eger II EI, 1994. Potentiation of μ-amonibutyric acid type a receptor-mediated chloride currents by novel halogenated compounds correlates with their abilities to induce general anesthesia. Mol Pharmacol 46:851–857.7969071
Mortensen B, Osvoll PO, Wolbeak T, 1998. In vitro screening for metabolic interactions among frequently occurring binary mixtures of volatile organic chemicals in Norwegian occupational atmosphere. Pharmacol Toxicol 83:49–56.9783320
Mumtaz MM, Sipes IG, Clewell HJ, 1993. Risk assessment of chemical mixtures: Biological and toxicologic issues. Fundam Appl Toxicol 21:258–269.8258379
Nakajima T, Sato A. 1974. Metabolic antagonism among benzene, toluene and m-xylene in vitro. Jpn J Ind Health 21:546–547.
Nakajima T, Wang RS. 1994. Induction of cytochrome P450 by toluene. Int J Biochem 12:1333–1340.
Nakajima T, Wang RS, Elovaara E, 1992. A comparative study on the contribution of cytochrome P450 isozymes to metabolism of benzene, toluene and trichloroethylene in rat liver. Biochem Pharmacol 43(2):251–257.1739413
Nakajima T, Wang RS, Elovaara E, 1993. Cytochrome P450-related differences between rats and mice in the metabolism of benzene, toluene and trichloroethylene in liver microsomes. Biochem Pharmacol 45(5):1079–1085.8461037
Neghab M, Stacey NH. 1997. In vitro interference with hepatocellular uptake of bile acids by xylene. Toxicology 120:1–10.9160103
*NTP. 2001. Ninth report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. June 2001.
Nylen P. 1996. Differing non-additive alterations in different parts of the nervous system of the rat. Food Chem Toxicol 34:1121–1123.9119324
Ogata M, Fujii T. 1979. Urinary excretion of hippuric acid and m -Methylhippuric acid administration of toluene and m-xylene mixture to rats. Int Arch Occup Environ Health 43:45–51.429068
Ogata M, Tomokuni K, Takatsuka Y. 1970. Urinary excretion of hippuric acid and — or p-methylhippuric acid in the urine of persons exposed to vapours of toluene and — or p-xylene as a test of exposure. Br J Ind Med 27:43–50.5418918
Olson BA, Gamberale F, Iregren A. 1985. Coexposure to toluene and p-xylene in man: Central nervous functions. Br J Ind Med 42:117–122.3970870
Pelekis M, Krishnan K. 1997. Assessing the relevance of rodent data on chemical interactions for health risk assessment purposes: A case study with dichloromethane-toluene mixture. Regul Toxicol Pharmacol 25:79–86.9056503
*Plappert U, Barthel E, Seidel HJ. 1994. Reduction of benzene toxicity by toluene. Environ Mol Mutagen 24:283–292.7851340
Prah JD, Case MW, Goldstein GM. 1998. 1998 equivalence of sensory responses to single and mixed volatile organic compounds at equimolar concentrations. Environ Health Perspect 106(11):739–744.9799190
*Purcell KJ, Cason GH, Gargas ML, 1990. In vivo metabolic interactions of benzene and toluene. Toxicol Lett 52:141–152.2377998
Rebert CS, Schwartz RW, Svendsgaard DJ, 1995. Combined effects of aspired solvents on the raťs auditory system. Toxicology 105:345–354.8571371
*Richer C-L, Chakrabarti S, Senecal-Quevillon M, 1993. Cytogenetic effects of low-level exposure to toluene, xylene, and their mixture on human blood lymphocytes. Int Arch Occup Environ Health 64:581–585.8314617
Romer KG, Federsel RJ, Freundt KF. 1986. Rise of inhaled toluene, ethyl benzene, m-xylene, or mesitylene in rat blood after treatment with ethanol. Bull Environ Contam Toxicol 37:874–876.3790759
*Rydzynski K, Korsak Z, Jedlínska U, 1992. The toxic effects of combined exposure to toluene and m-xylene in animals. IV. Liver ultrastructure after subchronic inhalatory exposure. Pol J Occup Med Environ Health 5(1):35–42.1392651
Sato A. 1993. Confounding factors in biological monitoring of exposure to organic solvents. Int Arch Occup Environ Health 65:S61–S67.8406940
*Sato A, Nakajima T. 1979. Dose-dependent metabolic interaction between benzene and toluene in vivo and in vitro. Toxicol Appl Pharmacol 48:249–256.473174
Simmons JE. 1994. Nephrotoxicity resulting from multiple chemical exposures and chemical interactions. In: Yang RSH, ed. Toxicology of chemical mixtures: Case studies, mechanisms, and novel approaches. San Diego, CA: Academic Press, Inc, 335–360.
Simmons JE. 1996. Application of physiologically based pharmacokinetic modeling to combination toxicology. Food Chem Toxicol 34:1067–1073.9119317
Simmons JE, Yang RSH, Berman E. 1995. Evaluation of the nephrotoxicity of complex mixtures containing organics and metals: Advantages and disadvantages of the use of real-world complex mixtures. Environ Health Perspect 103:67–71.
Snyder R. 1984. The benzene problem in historical perspective. Fundam Appl Toxicol 4:692–699.6510600
Snyder R. 1994. A perspective on benzene leukemogenesis. Crit Rev Toxicol 24(3):177–209.7945890
Snyder R, Kocsis JJ. 1975. Current concepts of chronic benzene toxicity. CRC Crit Rev Toxicol 3:265–288.1097190
Snyder R, Dimitriadis E, Guy R, 1989. Studies on the mechanism of benzene toxicity. Environ Health Perspect 82:31–35.2792049
Snyder R, Longacre SL, Sammett D, 1983. Relationship between the toxicity and metabolism of benzene. In: Mehlman MA, ed. Carcinogenicity and toxicity of benzene. Princeton: Princeton Scientific Publishers Inc., 23–36.
Snyder R, Witz G, Goldstein BD. 1993. The toxicology of benzene. Environ Health Perspect 100:293–306.8354177
Speck B, Moeschlin S. 1968. The effect of toluene, xylenes, chloramphenicol, and thioracil on bone marrow. Schweiz Med Wochenschr 98:1684–1686.5698350
Susheela AK, Bhatnagar M. 1993. Fluoride toxicity: A biochemical and scanning electron microscopic study of enamel surface of rabbit teeth. Arch Toxicol 67:573–579.8285857
*Tardif R, Charest-Tardif G, Brodeur J. 1996. Comparison of the influence of binary mixtures versus a ternary mixture of inhaled aromatic hydrocarbons on their blood kinetics in the rat. Arch Toxicol 70:405–413.8740534
*Tardif R, Charest-Tarif G, Brodeur J, 1997. Physiologically based pharmacokinetic modeling of a ternary mixture of alkyl benzenes in rats and humans. Toxicol Appl Pharmacol 144:120–134.9169076
*Tardif R, Laparé S, Charest-Tardif G, 1995. Physiologically-based pharmacokinetic modeling of a mixture of toluene and xylene in humans. Risk Anal 15(3):335–342.7604167
*Tardif R, Lapare S, Krishnan K, 1993a. A descriptive and mechanistic study of the interaction between toluene and xylene in humans. Int Arch Occup Environ Health 65:S135–S137.8406910
*Tardif R, Lapare S, Krishnan K, 1993b. Physiologically based modeling of the toxicokinetic interaction between toluene and m-xylene in the rat. Toxicol Appl Pharmacol 120:266–273.8511796
*Tardif R, Lapare S, Plaa GL, 1991. Effect of simultaneous exposure to toluene and xylene on their respective biological exposure indices in humans. Int Arch Occup Environ Health 63:279–284.1743770
*Tardif R, Plaa GL, Brodeur J. 1992. Influence of various mixtures of inhaled toluene and xylene on the biological monitoring of exposure to these solvents in rats. Can J Physiol Pharmacol 70:385–393.1600471
Tassaneeyakul W, Birkett DJ, Edwards JW, 1996. Human cytochrome P450 isoform specificity in the regioselective metabolism of toluene and o-, and p-xylene. J Pharmacol Exp Ther 276(1):101–108.8558417
*Toftgard R, Nilsen OG. 1981. Induction of cytochrome P-450 in rat liver after inhalation of aromatic organic solvents. In: Industrial and environmental xenobiotics: Metabolism and pharmacokinetics of organic chemicals and metals: proceedings of an international conference held in Prague, Czechoslovakia, 27–30 May 1980. New York: Springer-Verlag, 307–317.
Toftgard R, Nilsen OG. 1982. Effects of xylene and xylene isomers on cytochrome P-450 and in vitro enzymatic activities in rat liver, kidney and lung. Toxicology 23:197–212.7112593
Travis CC, Fox MT, Simmons M, 1992. Co-exposure to gasoline vapor decreases benzene metabolism in Fischer-344 rats. Toxicol Lett 62:231–240.1412508
Tsuruta H. 1996. Skin absorption of solvent mixtures: Effect of vehicles on skin absorption of toluene. Ind Health 34:369–378.8908847
*Tunek A, Hosgstedt B, Olofsson T. 1982. Mechanism of benzene toxicity: Effects of benzene and benzene metabolites on bone marrow cellularity, number of granulopoietic stem cells and frequency of micronuclei in mice. Chem Biol Interact 39:129–138.7060224
*Tunek A, Olofsson T, Berlin M. 1981. Toxic effects of benzene and benzene metabolites on granulopoietic stem cells and bone marrow cellularity in mice. Toxicol Appl Pharmacol 59:149–156.7256752
*Vodicková L, Frantík E, Vodicková A. 1995. [Neurotropic effects and blood levels of solvents at combined exposures: binary mixtures of toluene, o-xylene and acetone in rats and mice] Cent Eur J Public Health 3(2):57–64.
*von Euler G. 1994. Toluene and dopaminergic transmission. In: Isaacson RL, Jensen KF, eds. The vulnerable brain and environmental risks. Volume 3: Toxins in air and water. New York: Plenum Press, 301–321.
Walden T, Spence L. 1997. Risk-based BTEX screening criteria for a groundwater irrigation scenario. Hum Ecol Risk Assess 3(4):699–722.
*Wallen M, Holm S, Nordqvist MB. 1985. Coexposure to toluene and p-xylene in man: Uptake and elimination. Br J Ind Med 42:111–116.3970869
Wallen M, Naslund PH, Nordqvist MB. 1984. The effects of ethanol on the kinetics of toluene in man. Toxicol Appl Pharmacol 76:414–419.6506069
Wang RS, Nakajima T, Tsuruta H, 1996. Effect of exposure to four organic solvents on hepatic cytochrome P450 isozymes in rat. Chem Biol Interact 99:239–252.8620572
Xiao G, Pan C, Cai Y, 1999. Effect of benzene, toluene, xylene on the semen quality of exposed workers. Chin Med J 112(8):709–712.11601277
*Yin S, Li G, Hu Y, 1987. Symptoms and signs of workers exposed to benzene, toluene or the combination. Ind Health 25:113–130.3679888
Yokoyama K, Araki S, Murata K, 1997. Postural sway frequency analysis in workers exposed to n-hexane, xylene, and toluene: Assessment of subclinical cerebellar dysfunction. Environ Res 74:110–115.9339223