# SUMMARY

Benzene, toluene, ethylbenzene, and xylenes frequently co-occur at hazardous waste sites. Various combinations of these chemicals are among the most frequently found binary mixtures in completed exposure pathways at hazardous waste sites. Media contaminated with these chemicals include air, water, and soil. Contamination of groundwater can result in volatilization into indoor air when the groundwater is used as household water. In addition, contamination of groundwater and subsurface soil can result in migration of these chemicals into basements as soil gas. The purposes of this profile are: (1) to evaluate data on the toxicology of mixtures of benzene, toluene, ethylbenzene, and xylenes (BTEX); (2) to evaluate data on the joint toxic actions (e.g., additive, less-than-additive, or greater-than-additive joint actions) of these chemicals in producing health hazards; and (3) to make recommendations for exposure-based assessments of the potential impact of joint toxic action of the mixture on public health.

No studies are available that directly characterize health hazards and dose-response relationships for exposures to “whole” mixtures of BTEX. Exposure to each of the individual chemicals can produce neurological impairment via parent chemical-induced changes in neuronal membranes. Benzene can additionally cause hematological effects, which may ultimately lead to aplastic anemia and acute myelogenous leukemia, and there is evidence that ethylbenzene is carcinogenic in other tissues. No studies were located that directly examined joint toxic actions of benzene, toluene, ethylbenzene, and xylenes on the nervous system, but additive joint neurotoxic action is plausible for environmental exposures based on predictions from physiologically based pharmacokinetic (PBPK) modeling studies with BTEX and a ternary mixture of its components, and supporting data from neurotoxicity interaction studies of binary component mixtures.

In the absence of data on toxic or carcinogenic responses to the whole mixture, possible health hazards from exposures to BTEX are best assessed using a component-based approach that considers both the shared (neurologic) and unique (hematologic/carcinogenic) critical effects of the constituent chemicals. A hazard index approach that assumes additive joint action and uses ATSDR Minimal Risk Levels (MRLs) and guidance values based on neurological impairment is recommended for exposure-based assessments of possible neurotoxic health hazards from the four components. The possible hematotoxic and carcinogenic hazards of BTEX exposures should be evaluated on the basis of benzene alone due to the causal relationship between the noncancer hematological effects of benzene and the development of leukemia, and the lack of a cancer risk value for ethylbenzene. It therefore is recommended that the cancer unit risk value for benzene be used to jointly assess possible hematotoxic and carcinogenic hazards from exposures to BTEX.