# PEER REVIEW

A peer review panel was assembled for this profile. The panel consisted of the following members:

1. Dr. Harvey Clewell
  KS Crump Group
  602 East Georgia Avenue
  Ruston, LA 71270
2. Dr. Kannan Krishnan
  Department of Occupational and Environmental Health
  University of Montreal School of Medicine
  2375 Chemin de la Cote Ste-Catherine
  Montreal, QuebecH3T 1A8, Canada
3. Dr. Christopher Borgert
  Applied Pharmacology and Toxicology, Inc.
  238 Turkey Creek
  10514 Palmetto Boulevard
  Alachua, FL 32615

All reviewers were selected in conformity with the conditions for peer review specified in Section 104(I)(13) of the Comprehensive Environmental Response, Compensation, and Liability Act, as amended.

Scientists from the Agency for Toxic Substances and Disease Registry (ATSDR) have reviewed the peer reviewers’ comments and determined which comments will be included in the profile. A listing of the peer reviewers’ comments not incorporated in the profile, with a brief explanation of the rationale for their exclusion, exists as part of the administrative record for this compound. A list of databases reviewed and a list of unpublished documents cited are also included in the administrative record.

The citation of the peer review panel should not be understood to imply its approval of the profile’s final content. The responsibility for the content of this profile lies with the ATSDR.