# Appendix D Background Information for Xylenes

This appendix summarizes information on the toxicokinetics, health effects, mechanisms of action, and health guidelines for xylenes. The summaries are mainly based on information presented in the ATSDR (1995) toxicological profile for xylenes and therefore do not represent reviews of the primary literature. The chemical structures for xylenes are included in Appendix E.

## D.1 Toxicokinetics

Xylenes are well absorbed by the inhalation and oral routes. Experimental studies with humans found that retention of the various isomers was similar following inhalation of either o-, m-, or p-xylene and averaged 63.6% (Sedivec and Flek 1976). Other investigators have estimated that between 49.8 and 72.8% of inhaled xylene is retained in humans (ATSDR 1995). There appear to be two phases of respiratory absorption; the first is apparently short, occurring within 15 minutes of initiation of exposure, and the second phase is longer (about 1 hour) and represents the establishment of an equilibrium between the inhaled xylene and blood (ATSDR 1995). Oral absorption data are limited, but indicate that almost complete absorption (87–92%) occurred in rabbits following ingestion of a 1.7–1.8 g dose of o-, m-, or p-xylene. Dermal absorption may occur via exposure to xylene vapors as well as through direct dermal contact with the liquid (ATSDR 1995). Xylenes are absorbed dermally to a much lesser extent than by inhalation or oral exposure, especially following dermal exposure to xylene vapor (Riihimaki and Pfaffli 1978). Absorption of m-xylene vapor through human skin was determined to be approximately 0.1–2% of that of via inhalation exposure (Riihimaki and Pfaffli 1978). Based on breath sampling and PBPK analysis following vapor exposure, the contribution to m-xylene body burden from the dermal route was estimated to be 1.8%. The rate of dermal absorption varied in two human studies of m-xylene, ranging from approximately 2 μg/cm^2^/minute in one study to 75–160 μg/cm^2^/minute in the other (Dutkiewicz and Tyras 1968; Engstrom et al. 1977).

Absorbed xylene is mainly distributed to lipid-rich tissues, particularly adipose and brain (ATSDR 1995). High uptake also occurs in well-perfused organs such as the liver and kidneys. Estimates of the amount of inhaled xylene accumulated in human adipose tissue range from 5 to 10% of the absorbed dose (Astrand 1982; Engstrom and Bjurstrom 1978). The level of xylenes detected in mouse fetal tissues (brain, liver, lung, kidney), which are low in lipids, was only 2% of that found in the maternal brain tissue, which contains large amounts of lipids (Ghantous and Danielsson 1986).

Metabolism of xylenes in humans occurs primarily by hepatic cytochrome P-450-catalyzed oxidation of a side-chain methyl group to yield methylbenzoic acids (o-, m-, or p-toluic acids), which are conjugated with glycine to form methylhippuric acids (ATSDR 1995; Gut et al. 1993; Tassaneeyakul et al. 1996). Important CYP isozymes involved in the methylhydroxylation include CYP2E1 and CYP2B1, and metabolism to methylhippuric acids accounts for almost all (>90%) of the absorbed dose in humans, regardless of the isomer, route of administration, or dose or duration of exposure. Minor metabolic pathways that account for <10% of the absorbed dose in humans include unchanged xylene in the exhaled breath, and methylbenzyl alcohols, o-toluic acid glucuronide, xylene mercapturic acid, and xylenols (dimethylphenols) in the urine. CYP1A2 appears to be involved in the formation of the minor phenolic metabolites. The metabolism of xylenes in rats and other laboratory animals is qualitatively similar to that of humans, although glucuronide conjugates make up a larger proportion of the urinary excretion products. A toxic metabolite of xylenes in rats and rabbits that has not been confirmed in humans appears to be methylbenzaldehyde (Carlone and Fouts 1974; Patel et al. 1978; Smith et al. 1982), which is formed by the action of alcohol dehydrogenase on methylbenzyl alcohol in lung and liver tissues. Some studies indicate that the metabolic differences in humans and animals may partly be explained by differences in the size of doses (ATSDR 1995).

In humans, about 95% of absorbed xylene isomers is excreted as urinary metabolites, almost exclusively as methylhippuric acids, with the most of the remaining amount eliminated unchanged in the exhaled air (ATSDR 1995). Less than 0.005 and 2% of the absorbed dose is excreted in the urine unchanged and as xylenols, respectively. There appear to be at least two distinct phases of elimination, a relatively rapid one (1-hour half-life) and a slower one (20-hour half-life, corresponding to elimination from the muscles and adipose tissue). PBPK modeling suggests that the urinary excretion of m-methylhippuric acid in humans following inhalation of m-xylene is linear at concentrations up to 500 ppm (Kaneko et al. 1991a, 1991b). Humans exposed to 100 or 200 ppm m-xylene for 7 hours excreted 54 and 61%, respectively, of the administered dose by 18 hours after exposure ended (Ogata et al. 1970). Following intermittent acute exposure to 23, 69, or 138 ppm m-xylene, excretion of m-methylhippuric acid peaked 6–8 hours after exposure began and subsequently decreased rapidly so that almost no xylene or methyhippuric acid was detected 24 hours later (Senczuk and Orlowski 1978).

PBPK models have been developed for inhalation exposure to m-xylene in rats and humans (Lapare et al. 1993; Tardif et al. 1993b, 1995).

## D.2 Health Effects

Health effects of mixed xylenes, o-xylene, m-xylene, and p-xylene appear to be similar, although the individual isomers are not necessarily equal in potency with respect to a particular effect (ATSDR 1995). Studies in humans and animals document that the central nervous system is a major and sensitive target of xylene toxicity by the inhalation and oral routes. Human experimental studies indicate that acute inhalation exposure to 100 ppm mixed xylene or 200 ppm m-xylene causes impaired short-term memory, impaired reaction time, performance decrements in numerical ability, and alterations in equilibrium and body balance (Gamberale et al. 1978; Riihimaki and Savolainen 1980; Savolainen and Linnavuo 1979; Savolainen and Riihimaki 1981; Savolainen et al. 1979, 1980, 1984, 1985a, 1985b). Case and occupational studies together provide suggestive supportive evidence that acute and chronic inhalation exposure to xylene or solvent mixtures containing xylene may also be associated with many neurotoxic effects (ATSDR 1995). Neurological effects in orally- or dermally-exposed humans have not been studied. Animal studies provide further evidence that mixed xylenes and individual isomers are neurotoxicants following inhalation exposure at concentrations ranging from 160 to 2,000 ppm. Signs of neurotoxicity observed in rats, mice, and gerbils following acute- and intermediate-duration inhalation exposure to various xylene isomers have included narcosis, prostration, incoordination, tremors, muscular spasms, labored respiration, behavioral changes, elevated auditory thresholds and hearing loss, and changes in brain enzyme activity and levels of brain proteins (ATSDR 1995). Neurotoxic effects were also induced in the offspring of rats exposed by inhalation during gestation, including impaired performance in tests for neuromotor abilities (Rotarod) and learning and memory (Morris water maze) and delayed ontogeny of the air righting reflex (ATSDR 1995; Hass and Jakobsen 1993). Effects indicative of central nervous system toxicity (e.g., increased latency of visual-evoked potentials, lethargy, tremors, convulsions, respiratory depression, weakness, unsteadiness, and hyperactivity) similarly occurred in animals following acute-, intermediate-, and chronic-duration oral exposure to xylenes, although most of these were serious nonthreshold effects that occurred at high doses (ATSDR 1995).

Xylene is irritating to the to the respiratory tract, eyes, and skin. Adverse respiratory effects that have been observed in humans and animals following acute-, intermediate-, and/or chronic-duration inhalation exposure xylene include nose and throat irritation, labored breathing, and pulmonary congestion, inflammation, and edema (ATSDR 1995). LOAELs for these effects are incompletely characterized, although there are reports of nose and throat irritation following acute-, and chronic-duration inhalation exposures to concentrations of 100–200 and 14 ppm, respectively (Hake et al. 1981; Nelson et al. 1943; Uchida et al. 1993).

Xylene can affect the liver and kidney effects at exposure levels higher than the LOAELs for neurological effects and respiratory irritation. Inhalation or oral exposure to mixed xylenes and/or individual isomers produced hepatic effects in animals that appear to have been generally mild and adaptive in nature, including hepatic cytochrome P-450 content, proliferation of hepatic endoplasmic reticulum, increased liver weight, decreased hepatic glycogen, decreased hexobarbital sleeping time, and/or congestion of liver cells (ATSDR 1995). Occupational studies provide suggestive evidence that humans exposed to high inhalation levels of solvent mixtures containing xylene may be at increased risk of developing renal dysfunction and/or damage (ATSDR 1995). Renal effects such as increased blood urea concentrations, decreased urinary clearance of endogenous creatinine, increased lysozymuria, increased urinary levels of $-glucuronidase, and increased urinary excretion of albumin, erythrocytes, and leukocytes were observed, but the effects are not solely attributable to xylene due to the confounding exposures. Kidney effects found in inhalation and oral studies in animals included increased renal enzyme activity, increased cytochrome P-450 content, and increased kidney weight without histopathological alterations.

Human and animal data provide no indications of adverse hematological effects following inhalation of xylene. In the past, chronic occupational exposure to xylene was thought to be associated with a variety of hematological effects. However, exposure in all cases was to solvent mixtures known or suspected to contain benzene, and because benzene causes leukemia and other blood dyscrasias in humans, these effects cannot be attributed solely to xylene (ATSDR 1995). Hematological effects were not observed in an occupational study of xylene-exposed workers in which no benzene was involved (Uchida et al. 1993), or in rats, dogs, or guinea pigs exposed by inhalation to 810 ppm mixed xylenes or 780 ppm o-xylene for intermediate durations (Carpenter et al. 1975; Jenkins et al. 1970).

Information on the developmental toxicity of xylenes in humans is limited to a few occupational studies that are inadequate for assessing the relationship between exposure to xylenes and developmental effects due to concurrent exposure to other solvents and small numbers of subjects (ATSDR 1995). In animals, inhalation exposure to mixed xylenes (500 ppm) or the individual isomers (350–700 ppm) produced fetotoxic effects in rats, mice, and rabbits, including increased incidences of skeletal variations in fetuses, delayed ossification, fetal resorptions, hemorrhages in fetal organs, and decreased fetal body weight (Balogh et al. 1982; Bio/dynamics 1983; Hass and Jakobsen 1993; Hudak and Ungvary 1978; Litton Bionetics 1978; Mirkova et al. 1983; Ungvary 1985; Ungvary and Tatrai 1985; Ungvary et al. 1980, 1981). The levels at which these effects occurred were generally maternotoxic (ATSDR 1995). Milder neurodevelopmental effects occurred in rats at lower gestational inhalation exposure levels (200–500 ppm) that did not induce maternal toxicity, including impaired performance in tests for neuromotor (Rotarod) and learning and memory (Morris water maze) abilities, and delayed ontogeny of the air righting reflex (ATSDR 1995; Hass and Jakobsen 1993). A LOAEL of 200 ppm for impaired Rotarod performance was identified in 1- and 2-day-old rat pups that were intermittently exposed to mixed xylenes during gestation (Hass and Jakobsen 1993). An oral study found that mixed xylenes-induced cleft plate and decreased fetal weight in mice exposed to maternally toxic doses (Marks et al. 1982), and a dermal study found changes in brain enzymes (cholinesterase, cytochrome) in the brain of fetal rats (Mirkova et al. 1979).

Information on the reproductive toxicity of xylenes in humans is limited to two studies that found an increased incidence of spontaneous abortions following paternal exposure (Taskinen et al. 1989) or maternal exposure (Taskinen et al. 1994). These findings are inconclusive due to study limitations including multiple chemical exposures and small population size. No reproductive effects were found in rats following inhalation of 500 ppm mixed xylenes from before mating through lactation (Bio/dynamics 1983), but only one generation was assessed and this was primarily a developmental toxicity study. No changes in the histology of the testes and accessory glands or circulating male hormone levels occurred in rats following exposure to 1,000 ppm mixed xylenes for 61 days (Nylen et al. 1989). No histopathological changes were found in reproductive tissues of male and female rats and mice following intermediate- or chronic-duration oral exposure to mixed xylene or its isomers at doses as high as 500–2,000 mg/kg/day (NTP 1986; Wolfe 1988a, 1988b).

Human carcinogenicity data consist of limited and inconclusive occupational studies that examined risks of cancer and leukemia among workers exposed to xylenes together with other solvents (Arp et al. 1983; Wilkosky et al. 1984). Animal carcinogenicity data for xylenes are limited to equivocal oral studies with mixed xylenes (Maltoni et al. 1983, 1985; NTP 1986), and dermal initiation/promotion studies suggesting that xylene may be a promoter for skin cancer and might also act as an initiator or cocarcinogen (Berenblum 1941; Pound 1970; Pound and Withers 1963). No animal carcinogenicity data for xylenes are available for inhalation exposure. The insufficiencies of the available data preclude concluding that there is a causal relationship between xylene exposure and cancer. Mixed xylenes and the individual xylene isomers have been tested for genotoxicity in a variety of in vitro and in vivo assays with predominantly negative results, indicating that xylenes are nongenotoxic (ATSDR 1995).

## D.3 Mechanisms of Action

The mechanisms by which xylene exerts its toxic effects are not completely understood, although a number of theories exist pertaining to induction of effects in the nervous system, developing fetus, lung, and kidney. The central nervous system toxicity observed during exposure to high concentrations of xylene has been attributed to the liposolubility of xylene in the neuronal membrane (Desi et al. 1967; EPA 1985; Gerarde 1959; Savolainen and Pfaffli 1980; Tahti 1992). It has been suggested that xylene disturbs the action of proteins essential to normal neuronal function. This is similar to the way general anesthetic agents work, (i.e., either by a disruption of the lipid environment in which membrane proteins function or by direct interaction with the hydrophobic/hydrophilic conformation of proteins in the membranes). Changes in levels of various neurotransmitters and lipid composition have been observed in several brain areas following acute- and intermediate-duration exposure to xylene (Andersson et al. 1981; Honma et al. 1983; Savolainen and Seppalainen 1979). It is unclear whether these represent direct effects of xylene or are secondary changes resulting from nonspecific central nervous system depression. Some authors have also suggested that metabolic intermediates, such as arene oxides or methylbenzaldehyde, may be responsible for the toxic effects of xylene (Savolainen and Pfaffli 1980). Oxidation of xylene to these intermediates by microsomal enzyme systems may occur within brain cells (Savolainen and Pfaffli 1980).

Inhibition of pulmonary microsomal enzymes has been observed by several investigators (Elovaara et al. 1987; Patel et al. 1978; Silverman and Schatz 1991; Smith et al. 1982; Stickney et al. 1989). The exact mechanism of the enzyme inhibition is unknown, but has been attributed to the formation of a toxic reactive metabolite (such as methylbenzaldehyde) that binds directly to microsomal protein and inactivates the microsomal enzymes (Patel et al. 1978; Smith et al. 1982). Direct effects on microsomal membrane fluidity and/or lipid content do not appear to be involved (Stickney et al. 1989).

The mechanism for xylene-related renal toxicity is unknown, but may be related to the formation of reactive metabolites and subsequent irritation or direct membrane fluidization (EPA 1985). In humans exposed to solvent mixtures containing xylene, the increased urinary levels of β-glucuronidase have been proposed to be due to a faster cellular turnover in the renal tubular epithelium because of a mild toxicity (Franchini et al. 1983). The lysozymuria and increase in urinary excretion of albumin may be indicative of potential damage to the renal tubules and renal glomeruli, respectively (Askergren 1982; Franchini et al. 1983).

The exact mechanism by which mixed xylenes produce toxic effects in fetuses has not been fully investigated. The information on mechanisms of neurotoxicity in the preceding paragraph is relevant to exposed offspring as well as adults. Based on results of studies with rats, p-xylene-induced delayed fetal development may be related to decreased levels of progesterone and estradiol (Ungvary et al. 1981). The reduced levels of these hormones may have been due to increased microsomal enzyme activity and increased hormone catabolism.

## D.4 Health Guidelines

ATSDR (1995) derived an acute-duration inhalation MRL of 1 ppm for mixed xylenes based on a LOAEL of 100 ppm for neurological effects (increased reaction times) in humans (Dudek et al. 1990) and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for human variability). Volunteers were exposed to xylenes for 4 hours.

ATSDR (1995) derived an intermediate-duration inhalation MRL of 0.7 ppm for mixed xylenes based on a LOAEL of 200 ppm for neurodevelopmental effects (reduced rotarod performance in offspring) in rats (Hass and Jakobsen 1993) and an uncertainty factor of 300 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 3 for human variability). The animals were exposed 6 hours/day on gestation days 4–20.

ATSDR (1995) derived a chronic-duration inhalation MRL of 0.1 ppm for mixed xylenes based on a LOAEL of 14 ppm for subjective neurological effects (symptoms including anxiety, forgetfulness, and inability to concentrate) and eye and respiratory tract irritation in humans (Uchida et al. 1993) and an uncertainty factor of 100 (10 for use of a LOAEL and 10 human variability). Workers were occupationally exposed to xylenes for an average of 7 years.

ATSDR (1995) derived an acute-duration oral MRL of 1 mg/kg/day for p-xylene based on a NOAEL of 125 mg/kg/day for neurological effects (altered visual evoked potentials) in rats (Dyer et al.1988) and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). The animals were administered a single dose of p-xylene in oil.

ATSDR (1995) derived an intermediate-duration oral MRL of 0.2 mg/kg/day for mixed xylenes based on a LOAEL of 150 mg/kg/day for renal toxicity (early chronic nephropathy) in rats (Condie et al. 1988) and an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability). The animals were administered mixed xylenes in oil by gavage daily for 90 days.

ATSDR (1995) derived an intermediate-duration oral MRL of 0.6 mg/kg/day for m-xylene based on a LOAEL of 800 mg/kg/day for hepatic toxicity (increased plasma alanine aminotransferase and plasma membrane damage) in rats (Elovaara et al. 1989) and an uncertainty factor of 1,000 (10 for use of a LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability). The animals were administered m-xylene in oil by gavage 5 days/week for 3.3 weeks.

ATSDR (1995) did not derive oral MRLs for o-xylene for any duration period, or chronic-duration oral MRLs for mixed xylenes or any xylene isomer, due to lack of suitable data.

The EPA IRIS database lists an oral RfD, but no inhalation RfC for xylenes (IRIS 2001). The RfD is based on a NOAEL of 250 mg/kg/day (converted to 179 mg/kg/day) for neurological effects in rats (NTP 1986) and an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 for human variability). The animals were administered mixed xylenes by gavage 5 days/week for 103 weeks. ACGIH (2001) recommends a TLV-TWA of 100 ppm and STEL/C of 150 ppm for xylene (o-, m-, and p-isomers) based on irritation in humans.

The NTP (2001) has not listed xylenes as a known or anticipated human carcinogen. EPA determined that mixed xylenes are not classifiable as to human carcinogenicity (Category D) based on no human data and inadequate animal data (IRIS 2001). IARC (1999b) concluded that xylenes are not classifiable as to their carcinogenicity (Group 3) based on inadequate evidence in humans and animals.

## D.5 References

ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Andersson K, Fuxe K, Nilsen OG, 1981. Production of discrete changes in dopamine and nonadrenaline levels and turnover in various parts of the rat brain following exposure to xylene, ortho-, meta-, and para-xylene, and ethylbenzene. Toxicol Appl Pharmacol 60:535–548. (As cited in ATSDR 1995.)7292492
Arp EW Jr., Wolf PH, Chekoway H. 1983. Lymphocytic leukemia and exposures to benzene and other solvents in the rubber industry. J Occup Med 25:598–602. (As cited in ATSDR 1995.)6886869
Askergren A. 1982. Organic solvents and kidney function. In: Mehlman MA, ed. Advances in modern environmental toxicology. Vol.2. Princeton Junction, NJ: Senate Press, 157–172. (As cited in ATSDR 1995.)
Astrand I. 1982. Work load and uptake of solvents in tissues of man. In: Mehlman MA, ed. Advances in modern environmental toxicology. Vol. 2. Princeton Junction, NJ: Senate Press, 141–152. (As cited in ATSDR 1995.)
ATSDR. 1995. Toxicological profile for xylenes. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Balogh T, Tatrai E, Barczai G, 1982. [Study of the embryotoxic effect of xylene mixtures.] Egeszsegtudomany 26:42–48. (As cited in ATSDR 1995.)
Berenblum I. 1941. The cocarcinogenic action of croton resin. Cancer Res 1:44–48.(As cited in ATSDR 1995.)
Bio/dynamics Inc. 1983. Parental and fetal reproduction toxicity study in rats with mixed xylenes. EPA/OTS public files. East Millstone, NJ: Bio/dynamics Inc. Document # FYI-AX-0983–0209. (As cited in ATSDR 1995.)
Carlone MF, Fouts JR. 1974. In vitro metabolism of p-xylene by rabbit lung and liver. Xenobiotica 4:705–715. (As cited in ATSDR 1995.)
Carpenter CP, Kinhead ER, Geary DJ, 1975. Petroleum hydrocarbon toxicity studies: V. Animal and human response to vapors of mixed xylenes. Toxicol Appl Pharmacol 33:543–558. (As cited in ATSDR 1995.)1188950
Condie LW, Hill JR, Borzelleca JF. 1988. Oral toxicology studies with xylene isomers and mixed xylenes. Drug Chem Toxicol 11:329–354. (As cited in ATSDR 1995.)3243184
Desi I, Kovacs F, Zahumenszky Z, 1967. Maze learning in rats exposed to xylene intoxication. Psychopharmacologia (Berl) 11:224–230. (As cited in ATSDR 1995.)
Dudek B, Gralewicz K, Jakubowski M, 1990. Neurobehavioral effects of experimental exposure to toluene, xylene and their mixture. Pol J Occup Med 3:109–116. (As cited in ATSDR 1995.)2132931
Dutkiewicz T, Tyras H. 1968. Skin absorption of toluene, styrene, and xylene by man. Br J Ind Med 25:243. (As cited in ATSDR 1995.)5663430
Dyer RS, Bercegeay MS, Mayo LM. 1988. Acute exposures to p-xylene and toluene alter visual information processing. Neurotoxicol Teratol 10:147–153. (As cited in ATSDR 1995.)3398823
Elovaara E, Engstrom K, Hayri L, 1989. Metabolism of antipyrine and m-xylene in rats after prolonged pretreatment with xylene alone or xylene with ethanol, Phenobarbital, or 3-methyl-cholanthrene. (As cited in ATSDR 1995.)
Elovaara E, Zitting A, Nickels J, 1987. m-Xylene inhalation destroys cytochrome P-450 in rat lung at low exposure. Arch Toxicol 61:21–26. (As cited in ATSDR 1995.)3439869
Engstrom J, Bjurstrom R. 1978. Exposure to xylene and ethylbenzene: II. Concentration in subcutaneous adipose tissue. Scand J Work Environ Health 4:195–203. (As cited in ATSDR 1995.)705286
Engstrom K, Husman K, Riihimaki V. 1977. Percutaneous absorption of m-xylene in man. Int Arch Occup Environ Health 39:181–189. (As cited in ATSDR 1995.)924688
EPA. 1985. Drinking water criteria document for xylenes. Cincinnati, OH: U.S. Environmental Protection Agency, Office of Health and Environmental Assessment, Environmental Criteria and Assessment Office for the Office of Drinking Water, Washington, DC. EPA-600/X-84–185 PB86–117942. (As cited in ATSDR 1995.)
Franchini I, Cavatorta A, Falzoi M, 1983. Early indicators of renal damage in workers exposed to organic solvents. Int Arch Occup Environ Health 52:1–9. (As cited in ATSDR 1995.)6603422
Gamberale F, Annwall G, Hultengren M. 1978. Exposure to xylene and ethylbenzene: III. Effects on central nervous functions. Scand J Work Environ Health 4:204–211. (As cited in ATSDR 1995.)705287
Gerarde HW. 1959. Toxicological studies on hydrocarbons: III. The biochemorphology of the phenylalkanes and phenylalkenes. Arch Ind Health 19:403–418. (As cited in ATSDR 1995.)
Ghantous H, Danielsson BR. 1986. Placental transfer and distribution of toluene, xylene and benzene, and their metabolites during gestation in mice. Biol Res Pregnancy Perinatol 7:98–105. (As cited in ATSDR 1995.)3778990
Gut I, Terelius Y, Frantík E, 1993. Exposure to various benzene derivatives differently induces cytochromes P450 2B1 and P450 2E1 in rat liver. Arch Toxicol 67:237–243.8517779
Hake CLR, Stewart RD, Wu A, 1981. p-Xylene: Development of a biological standard for the industrial worker. Report to the National Institute for Occupational Safety and Health, Cincinnati, OH, by the Medical College of Wisconsin, Inc., Milwaukee, WI. PB82–152844. (As cited in ATSDR 1995.)
Hass U, Jakobsen BM, 1993. Prenatal toxicity of xylene inhalation in the rat: A teratogenicity and postnatal study. Pharmacology and Toxicology 73:20–23. (As cited in ATSDR 1995.)8234186
Honma T, Sudo A, Miyagawa M, 1983. Significant changes in the amounts of neurotransmitter and related substances in rat brain induced by subacute exposure to low levels of toluene and xylene. Ind Health 21:143–151. (As cited in ATSDR 1995.)6138322
Hudak A, Ungvary G. 1978. Embryotoxic effects of benzene and it’s methyl derivatives: Toluene, xylene. Toxicology 11:55–63. (As cited in ATSDR 1995.)705804
IARC. 1999b. Monographs on the evaluation of carcinogenic risks to humans. Xylenes. In: Volume 71 Part Three. Re-evaluation of some organic chemicals, hydrazine, and hydrogen peroxide. Lyon, France: World Health Organization, 1189–1208.
IRIS. 2001. Xylenes. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0270.htm.
Jenkins LJ, Jones RA, Siegel J. 1970. Long-term inhalation screening studies of benzene, toluene, o-xylene, and cumene on experimental animals. Toxicol Appl Pharmacol 16:818–823. (As cited in ATSDR 1995.)4987190
Kaneko T, Endoh K, Sato A. 1991a. Biological monitoring of exposure to organic solvent vapors. I. A physiological simulation model of m-xylene pharmacokinetics in man. Yamanashi Medical Journal 6(3):127–135. (As cited in ATSDR 1995.)
Kaneko T, Endoh K, Sato A. 1991b. Biological monitoring of exposure to organic solvent vapors. II. Simulation studies using a physiological pharmacokinetic model of m-xylene. Yamanashi Medical Journal 6(3):137–149. (As cited in ATSDR 1995.)
Lapare S, Tardiff R, Brodeur J. 1993. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air. I. Toluene and m-xylene. Int Arch Environ Health 64:569–580. (As cited in ATSDR 1995.)
Litton Bionetics. 1978. Teratology study in rats xylene (final report). EPA/OTS public files. Kensington, MD: Litton Bionetics. Document No. 878210350. (As cited in ATSDR 1995.)
Maltoni C, Conti B, Cotti G. 1983. Benzene: A Multipotential carcinogen: Results of long-term bioassays performed at the Bologna Institute of Oncology. Am J Ind Med 4:589–630. (As cited in ATSDR 1995.)6353911
Maltoni C, Conti B, Cotti G, 1985. Experimental studies on benzene carcinogenicity at the Bologna Institute of Oncology: Current results and ongoing research. Am J Ind Med 7:415–446. (As cited in ATSDR 1995.)4003403
Marks TA, Ledoux TA, Moore JA. 1982. Teratogenicity of a commercial xylene mixture in the mouse. J Toxicol Environ Health 9:97–105. (As cited in ATSDR 1995.)7062354
Mirkova E, Hinkova L, Vassileva L, 1979. Xylene neurotoxicity in pregnant rats and fetuses. Activ Nerv Supp (Praha) 21:265–268. (As cited in ATSDR 1995.)
Mirkova E, Zaikov C, Antov G, 1983. Prenatal toxicity of xylene. J Hyg Epidemiol Microbiol Immunol 27:337–343. (As cited in ATSDR 1995.)
Nelson KW, Ege JF Jr., Ross M, 1943. Sensory response to certain industrial solvent vapors. J Ind Hyg Toxicol 25:282–285. (As cited in ATSDR 1995.)
NTP. 1986. National Toxicology Program technical report on the toxicology and carcinogenesis studies of xylenes (mixed) (60% m-xylene, 14% p-xylene, 9% o-xylene, and 17% ethylbenzene) (CAS No. 1330–20-7) in F344/N rats and B6C3F1 mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institutes of Health, National Toxicology Program. NTP TR 327. NIH Publication No. 87–2583. (As cited in ATSDR 1995.)
NTP. 2001. Ninth report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. June 2001.
Nylen P, Ebendal T, Eriksdotter-Nilsson M, 1989. Testicular atrophy and loss of nerve growth factor-immunoreactive germ cell line in rats exposed to n-hexane and a protective effect of simultaneous exposure to toluene or xylene. Arch Toxicol 63:296–307. (As cited in ATSDR 1995.)2764718
Ogata M, Tomokuni K, Takatsuka Y. 1970. Urinary excretion of hippuric acid and — or p-methylhippuric acid in the urine of persons exposed to vapours of toluene and — or p-xylene as a test of exposure. Br J Ind Med 27:43–50. (As cited in ATSDR 1995.)5418918
Patel JM, Harper C, Drew RT. 1978. The biotransformation of p-xylene to a toxic aldehyde. Drug Metab Dispos 6:368–374. (As cited in ATSDR 1995.)28915
Pound AW. 1970. Induced cell proliferation and the initiation of skin tumour formation in mice by ultraviolet light. Pathology 2:269–275. (As cited in ATSDR 1995.)5520772
Pound AW, Withers HR. 1963. The influence of some irritant chemicals and scarification on tumour initiation by urethane in mice. Br J Cancer 17:460–470. (As cited in ATSDR 1995.)14062492
Riihimaki V, Pfaffli P. 1978. Percutaneous absorption of solvent vapors in man. Scand J Work Environ Health 4:73–85. (As cited in ATSDR 1995.)644269
Riihimaki V, Savolainen K. 1980. Human exposure to m-xylene: Kinetics and acute effects on the central nervous system. Ann Occup Hyg 23:411–422. (As cited in ATSDR 1995.)7258933
Savolainen H, Pfaffli P. 1980. Dose-dependent neurochemical changes during short-term inhalation exposure to m-xylene. Arch Toxicol 45:117–122. (As cited in ATSDR 1995.)7469788
Savolainen H, Seppalainen AM. 1979. Biochemical and physiological effects of organic solvents on rat axon membranes isolated by a new technique. Neurotoxicology 1:467–477. (As cited in ATSDR 1995.)
Savolainen K, Linnavuo M. 1979. Effects of m-xylene on human equilibrium measured with a quantitative method. Acta Pharmacol Toxicol 44:315–318. (As cited in ATSDR 1995.)
Savolainen K, Riihimaki V. 1981. An early sign of xylene effect on human equilibrium system. Acta Pharmacol Toxicol 48:279–283. (As cited in ATSDR 1995.)
Savolainen K, Kekoni J, Riihimaki V, 1984. Immediate effects of m-xylene on the human central nervous system. Arch Toxicol Suppl 7:412–417. (As cited in ATSDR 1995.)6596009
Savolainen K, Riihimaki V, Linnoila M. 1979. Effects of short-term xylene exposure on psychophysiological functions in man. Int Arch Occup Environ Health 44:201–211. (As cited in ATSDR 1995.)536046
Savolainen K, Riihimaki V, Luukkonen R, 1985a. Changes in the sense of balance correlate with concentrations of m-xylene. Br J Ind Med 42:765–769.4063219
Savolainen K, Riihimaki V, Muona O, 1985b. Conversely exposure-related effects between atmospheric m-xylene concentrations and human body sense of balance. Acta Pharmacol Toxicol 57:67–71.
Savolainen K, Riihimaki V, Seppalainen AM, 1980. Effects of short-term m-xylene exposure and physical exercise on the central nervous system. Int Arch Occup Environ Health 45:105–121. (As cited in ATSDR 1995.)7364487
Senczuk W, Orlowski J. 1978. Absorption of m-xylene vapours through the respiratory track and excretion. Br J Ind Med 35:50–55. (As cited in ATSDR 1995.)629889
Silverman DM, Schatz RA. 1991. Pulmonary microsomal alterations following short-term low-level inhalation of para-xylene in rats. Toxicology 65:271–281. (As cited in ATSDR 1995.)1992561
Smith BR, Plummer JL, Wolf CR, 1982. p-Xylene metabolism by rabbit lung and liver and its relationship to the selective destruction of pulmonary cytochrome P-450. J Pharmacol Exp Ther 223:736–742. (As cited in ATSDR 1995.)7143236
Stickney JA, Roberts AE, Silverman DM, 1989. The effect of m-xylene on rat lung benzo[a]pyrene metabolism and microsomal membrane lipids: Comparison with p-xylene. Toxicology 58:155–165. (As cited in ATSDR 1995.)2799823
Tahti H. 1992. The neurotoxicity of organic-solvents, studied with in vitro models. Alternatives to Labor Anim 20:290–296. (As cited in ATSDR 1995.)
Tardif R, Laparé S, Charest-Tardif G, 1995. Physiologically-based pharmacokinetic modeling of a mixture of toluene and xylene in humans. Risk Anal 15(3):335–342.7604167
Tardif R, Lapare S, Krishnan K, 1993b. Physiologically based modeling of the toxicokinetic interaction between toluene and m-xylene in the rat. Toxicol Appl Pharmacol 120:266–273. (As cited in ATSDR 1995.)8511796
Taskinen H, Antilla A, Lindbohm ML, 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15:345–352.2799322
Taskinen H, Kyyronen P, Hemminki K, 1994. Laboratory work and pregnancy outcome. J Occup Medicine 36(6):311–319. (As cited in ATSDR 1995.)
Tassaneeyakul W, Birkett DJ, Edwards JW, 1996. Human cytochrome P450 isoform specificity in the regioselective metabolism of toluene and o-, and p-xylene. J Pharmacol Exp Ther 276(1):101–108.8558417
Uchida Y, Nakatsuka H, Ukai H, 1993. Symptoms and signs in workers exposed predominantly to xylenes. Int Arch Occup Environ Health 64:597–605. (As cited in ATSDR 1995.)8314620
Ungvary G. 1985. The possible contribution of industrial chemicals (organic solvents) to the incidence of congenital defects caused by teratogenic drugs and consumer goods—an experimental study. Prog Clin Biol Res 160:295–300. (As cited in ATSDR 1995.)
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its allkyl derivatives in mice, rats and rabbits. Arch Toxicol [Supplement to] 8:425–430. (As cited in ATSDR 1995.)
Ungvary G, Tatrai E, Hudak A, 1980. Studies on the embryotoxic effects of ortho-, meta- and para-xylene. Toxicology 18:61–74. (As cited in ATSDR 1995.)7210024
Ungvary G, Varga B, Horvath E, 1981. Study on the role of maternal sex steroid production and metabolism in the embryotoxicity of para-xylene. Toxicology 19:263–268. (As cited in ATSDR 1995.)7233451
Wilcosky TC, Checkoway H, Marshall EG, 1984. Cancer mortality and solvent exposures in the rubber industry. Am Ind Hyg Assoc J 45:809–811. (As cited in ATSDR 1995.)6549104
Wolfe GW. 1988a. Subchronic toxicity study in rats with m-xylene. Report by Hazelton Laboratories Amercia, Inc., Rockville MD. Sponsored by Dynamic Corporation, Rockville, MD. (As cited in ATSDR 1995.)
Wolfe GW. 1988b. Subchronic toxicity study in rats with p-xylene. Report by Hazelton Laboratories Amercia, Inc., Rockville MD. Sponsored by Dynamic Corporation, Rockville, MD. (As cited in ATSDR 1995.)