# Appendix C Background Information for Ethylbenzene

This appendix summarizes information on the toxicokinetics, health effects, mechanisms of action, and health guidelines for ethylbenzene. The summaries are mainly based on information presented in the ATSDR (1999b) toxicological profile for ethylbenzene and therefore do not represent reviews of the primary literature. The chemical structure for ethylbenzene is included in Appendix E.

## C.1 Toxicokinetics

Ethylbenzene is well absorbed in humans via the inhalation and dermal routes of exposure, although oral absorption data in humans are lacking (ATSDR 1999b). For example, volunteers exposed for 8 hours to ethylbenzene at concentrations of 23–85 ppm were shown to retain 64% of the inspired vapor, with only trace amounts detected in expired air (Bardodej and Bardodejova 1970). Another inhalation study that involved humans exposed to similar levels of ethylbenzene demonstrated mean retention rates of 49%, suggesting possible variability of absorption rates among individuals (Gromiec and Piotrowski 1984). Dermal absorption rates of 24–33 and 0.11–0.23 mg/cm^2^/hour have been measured for male subjects exposed to liquid ethylbenzene and ethylbenzene from aqueous solutions, respectively (Dutkiewicz and Tyras 1967). The average amounts of ethylbenzene absorbed after volunteers immersed one hand for up to 2 hours in an aqueous solution of 112 or 156 mg/L ethylbenzene were 39.2 and 70.7 mg ethylbenzene, respectively. Animal data support the human inhalation and dermal findings and further indicate that absorption rates are high following oral exposure as well, as indicated by 72–92% urinary recovery of single oral doses in rats and rabbits (Climie et al. 1983; El Masri et al. 1956).

Information on the distribution of ethylbenzene in humans is available from one inhalation study indicating rapid distribution to adipose tissues throughout the body (Engstrom and Bjurstrom 1978). Oral and inhalation studies in animals support these results (Chin et al. 1980a, 1980b; Climie et al.1983). Ethylbenzene is accumulated primarily in the liver, kidney, and fat. In rats, the concentrations of ethylbenzene in perirenal adipose tissue were reported to increase, although not linearly, with increasing concentrations of ethylbenzene and in a mixture of solvent vapors containing ethylbenzene (Elovaara et al. 1982; Engstrom et al. 1985). The less-than-linear increase of ethylbenzene in adipose tissue with increasing dose was partially attributed to the induction of drug-metabolizing enzymes occurring with increasing exposure concentrations, altered blood flow to adipose tissue, changes in lung excretion, and changes in the distribution of ethylbenzene in different tissues.

Ethylbenzene is metabolized in humans mainly through hepatic cytochrome P-450-mediated side chain oxidation (hydroxylation) to initially form 1-phenylethanol, from which several metabolites are produced that are excreted in the urine (ATSDR 1999b). Isozymes involved in the initial oxidation include CYP2E1 and CYP1A2 (Gut et al. 1993). The major urinary metabolites of ethylbenzene in humans exposed via inhalation are mandelic acid (approximately 64–71%) and phenylglyoxylic acid (approximately 19–25%) (Bardodej and Bardodejova 1970; Engstrom et al. 1984). Minor pathways (e.g., ring hydroxylation) in humans yield hydroxylated derivatives (e.g., p-hydroxyacetophenone, m-hydroxyacetophenone, 1-phenyl-1,2-ethanediol, acetophenone, 2-hydroxyacetophenone, and 4-ethylphenol) that are conjugated with glucuronide or sulfate. The principal metabolic pathway in rats is believed to begin with hydroxylation of the side chain as in humans, although the major urinary metabolites following inhalation or oral exposure were identified as hippuric and benzoic acids (approximately 38%), 1-phenylethanol (approximately 25%), and mandelic acid (approximately 15–23%), with phenylglyoxylic acid making up only 10% of the metabolites (Climie et al. 1983; Engstrom 1984; Engstrom et al. 1985). Both in vivo studies using rats and in vitro studies using rat liver microsomes showed that 4-ethylphenol was also produced from ethylbenzene, perhaps by rearrangement of corresponding arene oxides (Bakke and Scheline 1970; Kaubisch et al. 1972). In rabbits, the most important metabolite is hippuric acid, which is probably formed by oxidative decarboxylation of phenylglyoxylic acid, and rabbits have been shown to excrete higher levels of glucuronidated metabolites than humans or rats (ATSDR 1999b).

The elimination of ethylbenzene has been studied in volunteers exposed by inhalation (ATSDR 1999b). The elimination of the major metabolite mandelic acid was reported to be rapid and biphasic, with half-lives of 3.1 hours for the rapid phase and 25 hours for the slow phase (Gromiec and Piotrowski 1984). During an 8-hour inhalation exposure to 4–46 ppm, 23% of the retained ethylbenzene was eliminated in the urine, and 14 hours following termination of exposure, an additional 44% of the retained ethylbenzene was eliminated. The highest excretion rate of urinary metabolites in humans exposed to ethylbenzene by inhalation occurred 6–10 hours after the beginning of exposure and metabolic efficiency was of the exposure dose (Gromiec and Piotrowski 1984; Yamasaki 1984). Data from occupational exposures have generally confirmed these results (Holz et al. 1995; Kawai et al. 1991, 1992; Ogata and Taguchi 1988). In animals, elimination of ethylbenzene metabolites following inhalation or oral exposure is rapid and occurs primarily via urinary metabolites, and to a much lesser degree, via the feces and expired carbon dioxide (ATSDR 1999b). Quantitative and qualitative differences between species were shown to exist in the percentages of metabolites excreted in the urine.

PBPK models have been developed for inhalation exposure to ethylbenzene in rats and humans (Tardif et al. 1997) and for dermal exposure to ethylbenzene in humans (Shatkin and Brown 1991). The dermal model describes the percutaneous absorption of ethylbenzene in dilute aqueous solution.

## C.2 Health Effects

Observations in humans and animals indicate that acute high level inhalation exposure to ethylbenzene causes central nervous system effects and irritation of the eyes and respiratory tract that were generally reversible following cessation of exposure (ATSDR 1999b). Information on neurological effects of ethylbenzene in humans is limited to an early report of dizziness accompanied by vertigo following acute exposure to 2,000–5,000 ppm ethylbenzene (Yant et al. 1930). Neurological effects of acute exposure to ≥2,000 ppm in rats, mice, and/or guinea pigs included decreased arousal and rearing, motor disturbances (gait, mobility, and righting reflex), decreased grip strength, increased landing foot splay, impaired psychomotor coordination, and narcotic effects such as prostration and reduced activity (Bio/dynamics 1986; Cragg et al. 1989; Molnar et al. 1986; Tegeris and Balster 1994; Yant et al. 1930). Increased motor activity and sporadic salivation were observed in rats at concentrations of 382–400 ppm and above (Cragg et al. 1989; Molnar et al. 1986). No signs of neurotoxicity were found in rabbits intermittently exposed to 2,400 ppm for 4 days or 1,610 ppm for 4 weeks (Cragg et al. 1989). Changes in dopamine and other biochemical alterations occurred in rats and rabbits exposed to 2,000 and 750 ppm, respectively, for 3–7 days (Andersson et al. 1981; Mutti et al. 1988; Romanelli et al. 1986). Evoked electrical activity in the brain was depressed in rats and mice acutely exposed to 245 and 342 ppm ethylbenzene, respectively (Frantik et al. 1994). Information on oral exposure is limited to a report in which no overt behavioral changes were observed in rats administered ethylbenzene by gavage for 6 months at concentrations ranging from 13.6 to 680 mg/kg/day (Wolf et al. 1956).

Ocular irritation, burning, and lacrimation occurred in humans acutely exposed to ≥1,000 ppm ethylbenzene vapor, and throat irritation and chest congestion were observed at ≥2,000 ppm, and (Cometto-Muniz and Cain 1995; Thienes and Haley 1972; Yant et al. 1930). Animal studies also showed ocular irritation and respiratory effects (e.g., pulmonary congestion and reduced respiratory rate) following acute exposure to concentrations generally above 1,000 ppm (ATSDR 1999b).

Animal data suggest that the liver and kidneys may be a target of toxicity for ethylbenzene. Acute inhalation exposure to high concentrations of ethylbenzene induced effects in the liver that were generally mild and indicative of adaptation (increased metabolism), including increased microsomal enzyme activity and other biochemical changes, ultrastructural changes, and increased liver weight (Bio/dynamics 1986; Cragg et al. 1989; Elovarra et al. 1985; Wolf et al. 1956). Hepatic histological effects that included necrosis were observed in mice, but not rats, that were exposed to concentrations of ethylbenzene up to 750 ppm for 2 years (NTP 1992). Renal effects manifested as histopathological changes (e.g., tubular swelling and hyperplasia), enzymatic changes, and increased organ weight were observed in a number of species following inhalation exposure to ethylbenzene following acute and longer-term exposure to concentrations generally ≥600 and ≥1,200 ppm, respectively (Andrew et al. 1981; Bio/dynamics 1986; Cragg et al. 1989; NTP 1992, 1996; Wolf et al. 1956).

Inconclusive information is available on the hematotoxic potential of ethylbenzene (ATSDR 1999b). Two studies involving long-term monitoring of workers occupationally exposed to ethylbenzene showed conflicting results with respect to effects on the hematopoietic system. One study (Angerer and Wulf 1985) reported an increase in the number of lymphocytes and a decrease in hemoglobin levels, whereas no adverse hematological effects were reported in the other study (Bardodej and Cirek 1988). There was likely simultaneous exposure to other chemicals in both of these studies. Platelet and leukocyte counts were increased in rats exposed to 782 ppm ethylbenzene for 4 weeks, although no hematological effects were observed in rats or other species exposed to similar or higher concentrations (Cragg et al. 1989; NTP 1992; Wolf et al. 1956).

The reproductive effects of ethylbenzene are incompletely characterized, although there are some data suggesting that the male and female reproductive systems may be a target of toxicity. No multigeneration studies have been performed. No histopathological changes were induced in the testes of rat, mice, or rabbits following inhalation exposure to ≤2,400 ppm ethylbenzene for 4 days, rats and mice exposed to ≤782 ppm for 4 weeks, or rabbits exposed to ≤1,610 ppm for 4 weeks (Bio/dynamics 1986; Cragg et al. 1989). There were no effects on sperm, length of the estrous cycle, or histopathology of reproductive organs in male or female rats or mice exposed to 975 ppm for 90 days, although chronic exposure to 750 ppm caused increased incidences of testicular tumors in rats (NTP 1992, 1999). Ungvary and Tatrai (1985) reported an increase in postimplantation death in the offspring of rats exposed to ≥138 ppm continuously during organogenesis and an increase in abortions in rabbits similarly exposed to 230 ppm. Fertility was reduced in female rats exposed for 3 weeks pre-gestation and during gestation to 1,000 ppm, but the investigators did not consider the effect to be significant (Andrew et al. 1981). Acute oral exposure to 500 or 1,000 mg/kg ethylbenzene decreased peripheral hormone levels and delayed the estrus cycle in female rats during the diestrus stage (Ungvary 1986). Decreased levels of hormones (e.g., luteinizing hormone, progesterone, and 17 β-estradiol) were accompanied by uterine changes (increased stromal tissue with dense collagen bundles and reduced lumen), but no dose response was noted.

Developmental toxicity studies in animals indicate that inhalation exposure to ethylbenzene can produce minimal fetotoxic effects at exposure levels that may or may not induce minimal maternal changes (ATSDR 1999b). Effects included skeletal anomalies and supernumerary ribs in offspring of rats that were intermittently exposed to 959 ppm of ethylbenzene during gestation (Andrew et al. 1981). Extra ribs and anomalies of the urinary tract occurred in fetuses of rats continuously exposed to 552 ppm ethylbenzene during gestation, and urinary tract anomalies were also increased in fetal mice similarly exposed to 115 ppm (Ungvary and Tatrai 1985).

Ethylbenzene was not genotoxic in most studies, although some marginal effects have been reported. Workers exposed to low levels of ethylbenzene in a styrene plant showed no increases in sister chromatid exchanges, DNA adduct formation, micronuclei, or DNA single-strand breaks in the peripheral lymphocytes (Holz et al. 1995). Micronucleated peripheral erythrocytes were not increased in mice that were exposed to 750 ppm ethylbenzene for 13 weeks (NTP 1999). Ethylbenzene was generally not mutagenic in bacteria or yeast cells in vitro, and did not induce sister chromatid exchanges or chromosomal aberrations in Chinese hamster cells (ATSDR 1999b). A weak positive response was observed when ethylbenzene was tested for sister chromatid exchanges in human lymphocytes in vitro, but only at a concentration that was toxic to the cells (Norppa and Vainio 1983). A positive response also was seen in mouse lymphoma cells when ethylbenzene was tested at a near lethal concentration (McGregor et al. 1988).

The carcinogenicity of ethylbenzene has been examined in three studies: an epidemiological study of humans occupationally exposed by inhalation (Bardodej and Cirek 1988), a chronic inhalation bioassay in rats and mice (Chan et al. 1998; NTP 1999), and a chronic oral study in rats (Maltoni et al. 1985). The results of both the human epidemiological study and the oral study in rats were inconclusive. The inhalation bioassay intermittently exposed rats and mice to ≤750 ppm ethylbenzene for 104 weeks and concluded that there was clear evidence of carcinogenic activity in male rats based on increased incidences of renal tubule neoplasms and testicular adenomas (Chan et al. 1998; NTP 1999). The inhalation study also concluded that there was some evidence of carcinogenic activity in female rats based on increased incidences of renal tubule adenoma, in male mice based on increased incidences of alveolar/ bronchiolar neoplasms, and in female mice based on increased incidences of hepatocellular neoplasms.

## C.3 Mechanisms of Action

Relatively little information exists regarding the mechanism of ethylbenzene toxicity. Most studies have focused on the possible mechanism of neurotoxicity. In vitro studies on the mechanism of toxicity of ethylbenzene have focused on the effect of this chemical on cell membranes, particularly that of the astrocyte (Engelke et al. 1993; Naskali et al. 1993, 1994; Sikkema et al. 1995; Vaalavirta and Tähti 1995a, 1995b). It has been suggested that changes in the structure and integrity of the cell membrane after partitioning of ethylbenzene into the lipid bilayer may be a mechanism of toxicity of ethylbenzene (Sikkema et al. 1995). Changes in the integrity of the cell membrane may subsequently affect the function of membrane, particularly as a barrier and in energy transduction, and in the formation of a matrix for proteins and enzymes. Engelke et al. (1993) showed that incubation of pig liver microsomes with ethylbenzene caused an accumulation of ethylbenzene in the microsomal membrane, which, in turn, increased the fluidity of the membrane. Although incubation of the microsomal membranes with ethylbenzene did not change the content of cytochrome P-450 or cytochrome b_5_ content, or the activities of nicotinamide adenine dinucleotide phosphate (oxidized form) (NADPH)-cytochrome P-450 reductase or nicotinamide adenine dinucleotide phosphate (reduced form) (NADH)-cytochrome b_5_ reductase, a change in the reduction kinetics of these enzymes was observed. The authors proposed that the observed change in kinetics may be due to a rearrangement of the cytochrome P-450 molecules in the microsomal membrane as a result of the accumulation of ethylbenzene in the membrane.

Vaalavirta and Tähti (1995a, 1995b) and Naskali et al. (1993, 1994) investigated the effect of ethylbenzene on the membrane of the rat astrocyte as an in vitro model for the membrane-mediated effects of solvents on the central nervous system. Cultured astrocytes from the cerebellum of neonatal Sprague-Dawley rats were sensitive to the effects of ethylbenzene, as measured by the inhibition of activity of Na^+^, K^+^-ATPase, and Mg^++^-ATPase (Vaalavirta and Tähti 1995a, 1995b). This effect was found to be dose-dependent (Naskali et al. 1994). Inhibition of these membrane-bound enzymes that regulate the ion channels of the membrane may disturb the ability of the cells to maintain homeostasis. Experiments with rat synaptosome preparations, similar to those using microsomal preparations by Engelke et al. (1993), showed that membrane fluidity was increased after exposure to ethylbenzene. ATPase and acetylcholinesterase activity were also decreased, as seen in the astrocyte preparations. Results from the in vitro studies described above are consistent with what would be expected of the interaction of a lipophilic chemical with cell membranes. However, there is no direct evidence that the interaction of ethylbenzene with astrocytes in vivo is the mechanism of neurological effects following acute exposure to high levels of ethylbenzene in humans or in animals.

The mechanism(s) of toxic effects of ethylbenzene on organs or systems other than the nervous system has not been elucidated, but is likely to be related to the formation of reactive metabolites that ultimately bind to cell macromolecules (ATSDR 1999b; NTP 1999).

## C.4 Health Guidelines

ATSDR (1999b) derived an intermediate-duration inhalation MRL of 1.0 ppm for ethylbenzene based on a NOAEL of 97 ppm for developmental effects (skeletal anomalies) in rats (Andrew et al. 1981). The animal NOAEL was converted to a NOAEL_(HEC)_ of 97 ppm and divided by an uncertainty factor of 100 (10 for extrapolation from animals to humans and 10 to account for human variability) to yield the MRL. The animals were exposed for 7 hours/day, 5 days/week for 3 weeks prior to mating and subsequently through gestation day 19.

No acute- or chronic-duration inhalation MRLs were derived for ethylbenzene due to a lack of appropriate data (ATSDR 1999b).

No acute-, intermediate-, or chronic-duration oral MRLs were derived for ethylbenzene due to a lack of appropriate data (ATSDR 1999b).

The EPA IRIS database lists an RfD and an RfC for ethylbenzene (IRIS 2001). The RfD is based on a NOAEL of 136 mg/kg/day (converted to 97 mg/kg/day) for liver and kidney toxicity in rats (Wolf et al. 1956) and an uncertainty factor of 1,000 (10 for subchronic-to-chronic extrapolation, 10 for extrapolation from animals to humans, and 10 for human variability). The animals were exposed to ethylbenzene in olive oil by gavage 5 days/week for 182 days.

The EPA RfC for ethylbenzene is based on a NOAEL of 100 ppm for developmental toxicity in rats and rabbits (Andrew et al. 1981; Hardin et al. 1981) and an uncertainty factor of 300 (3 for extrapolation from animals to humans, 10 for human variability, and 10 for database deficiencies) (IRIS 2001). The animals were exposed 6–7 hours/day during days 1–19 (rats) and days 1–24 (rabbits) of gestation.

ACGIH (2001) recommends a TLV-TWA of 100 ppm and STEL/C of 125 ppm for ethylbenzene based on irritation and central nervous system effects.

The NTP (2001) has not listed ethylbenzene as a known or anticipated human carcinogen. EPA determined that ethylbenzene is not classifiable as to human carcinogenicity (Category D) due to lack of animal bioassay and human data (IRIS 2001). The NTP and EPA assessments predate the positive findings of the NTP (1999) carcinogenesis bioassay in rats and mice. IARC (2000) concluded that ethylbenzene is possibly carcinogenic to humans (Group 2B) based on inadequate evidence in humans and sufficient evidence in animals.

## C.5 References

ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Andersson K, Fuxe K, Nilsen OG, 1981. Production of discrete changes in dopamine and nonadrenaline levels and turnover in various parts of the rat brain following exposures to xylene, ortho-, meta-,and para-xylene, and ethylbenzene. Toxicol Appl Pharmacol 60:535–548.7292492
Andrew FD, Buschbom RL, Cannon WC, 1981. Teratologic assessment of ethylbenzene and 2-ethoxyethanol. Richland, WA: Batelle Pacific Northwest Laboratory. PB83–208074., 108. (As cited in ATSDR 1999b.)
Angerer J, Wulf H. 1985. Occupational chronic exposure to organic solvents. XI. Alkylbenzene exposure of varnish workers: Effects on hematopoietic system. Int Arch Occup Environ Health 56:307–321.4066054
ATSDR. 1999b. Toxicological profile for ethylbenzene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Bakke OM, Scheline RR. 1970. Hydroxylation of aromatic hydrocarbons in the rat. Toxicol Appl Pharmacol 16:691–700. (As cited in ATSDR 1999b.)5422210
Bardodej Z, Bardodejova E. 1970. Biotransformation of ethylbenzene, styrene, and alpha-methylstyrene in man. Am Ind Hyg Assoc J 31:1–5. (As cited in ATSDR 1999b.)4985565
Bardodej Z, Cirek A. 1988. Long-term study on workers occupationally exposed to ethylbenzene. J Hyg Epidemiol Microbial Immunol 32:1–5. (As cited in ATSDR 1999b.)
Bio/dynamics. 1986. A four day inhalation study of ethylbenzene in the rat, mouse, and rabbit. Submitted to the US EPA/OTS Public Files. Document #86870000432. (As cited in ATSDR 1999b.)
Chan PC, Haseman JK, Mahler J, 1998. Tumor induction in F344/N rats and B6C3F1 mice following inhalation exposure to ethylbenzene. Toxicol Lett 99:23–32. (As cited in IARC 2000.)9801027
Chin BH, McKelvey JA, Calisti LJ, 1980a. A comparison of in vivo and in vitro (tissue explant) techniques: Metabolic profile of ethylbenzene in the rat and the dog. Bull Environ Contam Toxicol 25:241–245. (As cited in ATSDR 1999b.)7426768
Chin BJ, McKelvey JA, Tyler TR, 1980b. Absorption, distribution, and excretion of ethylbenzene, ethylcyclohexane, and methylethylbenzene isomers in rats. Bull Env Contam Toxicol 24:477–483. (As cited in ATSDR 1999b.)
Climie IJG, Hutson DH, Stoydin G. 1983. The metabolism of ethylbenzene hydroperoxide in the rat. Xenobiotica 13:611–618. (As cited in ATSDR 1999b.)6673374
Cometto-Muniz JE, Cain WS. 1995. Relative sensitivity of the ocular trigeminal, nasal trigeminal and olfactory systems to airborne chemicals. Chemical Senses 20(2):191–198. (As cited in ATSDR 1999b.)7583011
Cragg ST, Clarke EA, Daly IW, 1989. Subchronic inhalation toxicity of ethylbenzene in mice, rats, and rabbits. Fundam Appl Toxicol 13(3):399–408. (As cited in ATSDR 1999b.)2612773
Dutkiewicz T, Tyras H. 1967. A study of the skin absorption of ethylbenzene in man. Brit J Ind Med 24:330–332. (As cited in ATSDR 1999b.)6073092
El Masri AM, Smith JN, Williams RT. 1956. The metabolism of alkylbenzenes: n-Propylbenzene and n-butylbenzene with further observations on ethylbenzene. Biochem J 64:50–56. (As cited in ATSDR 1999b.)13363805
Elovaara E, Engstrom K, Nickels J, 1985. Biochemical and morphological effects of long-term inhalation exposure of rats to ethylbenzene. Xenobiotica. 15:299–308. (As cited in ATSDR 1999b.)4024664
Elovaara E, Engstrom K, Vainio H. 1982. Unaltered metabolism of m-xylene in the presence of ethylbenzene. Dev Biochem 23:265–268. (As cited in ATSDR 1999b.)
Engelke M, Bergmann U, Diehl HA. 1993. Fluidity of the microsomal membrane and cytochrome P450 reduction kinetics of pig liver microsomes as a consequence of organic solvent impact. Xenobiotica 23(1):71–78. (As cited in ATSDR 1999b.)8484265
Engstrom J, Bjurstrom R. 1978. Exposure to xylene and ethylbenzene. II. Concentration in subcutaneous adipose tissue. Scand J Work Environ Health 4:195–203. (As cited in ATSDR 1999b.)705286
Engstrom K, Elovaara E, Aitio A. 1985. Metabolism of ethylbenzene in the rat during long-term intermittent inhalation exposure. Xenobiotica 15:281–286. (As cited in ATSDR 1999b.)4024662
Engstrom K, Riihinaki V, Laine A. 1984. Urinary disposition of ethylbenzene and —xylene in man following separate and combined exposure. Int Arch Occup Environ Health 54:355–363. (As cited in ATSDR 1999b.)6511105
Frantik E, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66(2):173–185. (As cited in ATSDR 1999b.)8055839
Gromiec JP, Piotroski JK. 1984. Urinary mandelic-acid as an exposure test for ethylbenzene. Int Arch Occup Environ Health 55:61–72. (As cited in ATSDR 1999b.)6526501
Gut I, Terelius Y, Frantík E, 1993. Exposure to various benzene derivatives differently induces cytochromes P450 2B1 and P450 2E1 in rat liver. Arch Toxicol 67:237–243.8517779
Hardin BD, Bond GP, Sikov MR, 1981. Testing of selected workplace chemicals for teratogenic potential. Scand J Work Environ Health 7 (Suppl. 4):66–75. (As cited in ATSDR 1999b.)7330632
Holz O, Scherer G, Brodtmeier S, 1995. Determination of low level exposure to volatile aromatic hydrocarbons and genotoxic effects in workers at a styrene plant. Environ Med 52(6):420–428. (As cited in ATSDR 1999b.)
IARC. 2000. Some industrial chemicals. Ethylbenzene. Volume 77. In: IARC Monographs on the evaluation of carcinogenic risks to humans. Lyon, France: World Health Organization, International Agency for Research on Cancer, 227–266.
IRIS. 2001. Ethylbenzene. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0051.htm.
Kaubisch N, Daly JW, Jerina DM. 1972. Arene oxides as intermediate in the oxidative metabolism of aromatic compounds. Isomerization of methyl-substituted arene oxides. Biochemistry 11:3080–3088. (As cited in ATSDR 1999b.)5041913
Kawai T, Mizunuma K, Yasugi T, 1991. Urinary methylhippuric acid isomer levels after occupational exposure to a xylene mixture. Int Arch Occup Environ Health 63(1):69–75.1856026
Kawai T, Yasugi T, Mizunuma K, 1992. Comparative evaluation of urinalysis and blood analysis as means of detecting exposure to organic solvents at low concentrations. Int Arch Occup Environ Health 64(4):223–234.1468790
Maltoni C, Conti B, Cotti G, 1985. Experimental studies on benzene carcinogenicity at the Bologna Institute of Oncology: Current results and ongoing research. Am J Ind Med 7:415–446. (As cited in ATSDR 1999b.)4003403
McGregor DB, Brown A, Cattanach P, 1988. Responses of the L5178Y tk+/tk− mouse lymphoma cell forward mutation assay: III. 72 Coded chemicals. Environ Mol Mutag 12:85–154. (As cited in ATSDR 1999b.)
Molnar J, Paksy KA, Naray M. 1986. Changes in the rat’s motor behaviour during 4-hr inhalation exposure to prenarcotic concentrations of benzene and its derivatives. Acta Physiol Hung 67:349–354. (As cited in ATSDR 1999b.)3751604
Mutti A, Falzoi H, Romanelli A, 1988. Brain dopamine as a target for solvent toxicity: Effects of some monocyclic aromatic hydrocarbons. (As cited in ATSDR 1999b.)
Naskali L, Engelke M, Tahti H, 1993. The effects of selected organic solvents on rat synaptosomal membrane fluidity and integral enzyme activities. Neurosci Res Commun 13(1):27–35. (As cited in ATSDR 1999b.)
Naskali L, Oksanen H, Tahti H. 1994. Astrocytes as targets for CNS effects of organic solvents in vitro. Neurotoxicology. 15(3):609–612. (As cited in ATSDR 1999b.)7854595
Norppa H, Vainio H. 1983. Induction of sister-chromatid exchanges by styrene analogues in cultured human lymphocytes. Mutat Res 116:379–387. (As cited in ATSDR 1999b.)6835253
NTP. 1992. Draft, Subchronic and chronic toxicity study of ethylbenzene: 90-day subchronic study report on inhalation exposure of F344/N rats B6C3F1 mice. Chicago, Illinois: National Toxicology Program. October 27, 1988. (As cited in ATSDR 1999b.)
NTP. 1996. Toxicology and carcinogenesis studies of ethylbenzene in F355/N rats and B6C3F1 mice. Inhalation studies TR-466. (DRAFT). (As cited in ATSDR 1999b.)
NTP. 1999. Toxicology and carcinogenesis studies of ethylbenzene in F344/N rats and B6C3F1 mice (Inhalation studies). U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. TR No. 466.
NTP. 2001. Ninth report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. June 2001.
Ogata M, Taguchi T. 1988. Simultaneous determination of urinary creatinine and metabolites of toluene, xylene, styrene, ethylbenzene and phenol by automated high performance liquid chromatography. Environ Health 61(½):131–140. (As cited in ATSDR 1999b.)
Romanelli A, Falzoi M, Mutti A, 1986. Effects of some monocyclic aromatic solvents and their metabolites on brain dopamine in rabbits. J Appl Toxicol 6(6):431–435. (As cited in ATSDR 1999b.)3805570
Shatkin JA, Brown HS. 1991. Pharmacokinetics of the dermal route of exposure to volatile organic chemicals in water: A computer simulation model. Environ Res 56(1):90–108. (As cited in ATSDR 1999b.)1915193
Sikkema J, De Bont J AM, Poolman B. 1995. Mechanisms of membrane toxicity of hydrocarbons. Microbiol Rev 59(2):201–222. (As cited in ATSDR 1999b.)7603409
Tardif R, Charest-Tarif G, Brodeur J, 1997. Physiologically based pharmacokinetic modeling of a ternary mixture of alkyl benzenes in rats and humans. Toxicol Appl Pharmacol 144:120–134.9169076
Tegeris JS, Balster RL. 1994. A comparison of the acute behavioral effects of alkylbenzenes using a functional observational battery in mice. Fund Appl Toxicol 22(2):240–250. (As cited in ATSDR 1999b.)
Thienes C, Haley TJ. 1972. Clinical toxicology. 5^th^ ed. Philadelphia, PA: Lea and Febiger, 126. (As cited in ATSDR 1999b.)
Ungvary G. 1986. Solvent effects on reproduction: Experimental Toxicity. 220:169–177. (As cited in ATSDR 1999b.)
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its alkyl derivatives in mice, rats and rabbits. Arch Toxicol (Suppl) 8:425–430. (As cited in ATSDR 1999b.)
Vaalavirta L, Tahti H. 1995a. Astrocyte membrane Na+, K(+)-ATPase and Mg(2+)-ATPase as targets of organic solvent impact. Life Sci 57(24):2223–2230. (As cited in ATSDR 1999b.)7475975
Vaalavirta L, Tahti H. 1995b. Effects of selected organic solvents on the astrocyte membrane ATPase in vitro. Clin Exper Pharmacol Physiol 22(4):293–294. (As cited in ATSDR 1999b.)7671444
Wolf MA, Rowe VK, McCollister DD, 1956. Toxicological studies of certain alkylated benzenes and benzene: Experiments on laboratory animals. AMA Arch Ind Health 14:387–398. (As cited in ATSDR 1999b.)13361560
Yamasaki Y. 1984. [The determination of urinary metabolites of ethylbenzene by high performance liquid chromatography]. Okayama Igakkai Zasshi 96:531–535. (Japanese). (As cited in ATSDR 1999b.)
Yant WP, Schrenk HH, Waite CP, 1930. Acute response of guinea pigs to vapors of some new commercial organic compounds. II. Ethylbenzene. Pub Health Rep 45:1241–1250. (As cited in ATSDR 1999b.)