# Appendix B Background Information for Toluene

This appendix summarizes information on the toxicokinetics, health effects, mechanisms of action, and health guidelines for toluene. The summaries are mainly based on information presented in the ATSDR (2000) toxicological profile for toluene and therefore do not represent reviews of the primary literature. The chemical structure for toluene is included in Appendix E.

## B.1 Toxicokinetics

Studies with humans and animals indicate that toluene is readily absorbed from the respiratory and gastrointestinal tracts and, to a lesser extent, through the skin (ATSDR 2000). Respiratory uptake was rapid in humans exposed to 80 ppm toluene, as shown by the appearance of toluene in the blood within 10–15 minutes of exposure (Hjelm et al. 1988). About 50% of deuterium-labeled toluene was absorbed from the lungs in volunteers exposed to 53 ppm for 2 hours during a period of light exercise (Lof et al. 1993). Seven humans exposed to 50 ppm toluene in a closed chamber showed an average retention of 83% of the inspired concentration (Benoit et al. 1985). Complete gastrointestinal absorption in humans was indicated by monitoring exhaled air for toluene and urine for toluene metabolites (hippuric acid and ortho-cresol) following oral administration of toluene as a 2 mg/minute infusion for 3 hours through a feeding tube into the stomach (Baelum et al. 1993). Complete absorption of orally administered toluene has also been observed in rats, although the rate of oral absorption was slower than pulmonary absorption (maximum blood levels were observed 1.5–3 hours and 15–30 minutes after administration, respectively) (Pyykko et al. 1977). The rate of dermal absorption of liquid toluene through human forearm skin was found to be slow, ranging from 14 to 23 mg/cm^2^/hour (Dutkiewicz and Tyras 1968). Dermal absorption of toluene vapor has been demonstrated in animals (ATSDR 2000). For example, dose and duration-related increases in whole body toluene levels were found in nude mice that were exposed to 300, 1,000, or 3,000 ppm toluene under conditions where there was no respiratory intake of toluene (Tsuruta 1989). The calculated skin absorption coefficient was 1.24 cm/hour. The skin absorption rates were 0.0009, 0.0046, and 0.0144 mg/cm^2^/hour for the 300, 1,000 and 3,000 ppm concentrations, respectively.

Distribution of absorbed toluene in humans and laboratory animals is characterized by preferential uptake in lipid-rich and highly vascular tissues such as the brain, bone marrow, and body fat (ATSDR 2000). Toluene is distributed between the plasma and red blood cells at approximately a 1:1 ratio in humans based on in vitro data and a 1:2 ratio in rats based on in vivo data (Lam et al. 1990). In the red blood cells, toluene appears to be associated with the hemoglobin rather than the cell membrane. The interaction of toluene with the red blood cell increases the amount of toluene that can be accommodated by the aqueous blood medium and facilitates transport of toluene to all areas of the body (including the brain) at a rate that is greater than if toluene was transported only in the plasma. Within the brain, toluene has a greater affinity for the areas that contain lipid-rich white matter, such as the brain stem and midbrain, rather than the areas with larger amounts of gray matter (Ameno et al. 1992; Bergman 1979).

The first step in toluene metabolism is catalyzed by several cytochrome P-450 species (ATSDR 2000; Gut et al. 1993; Nakajima and Wang 1994; Nakajima et al. 1991, 1992a, 1992b, 1993, 1997; Tassaneeyakul et al. 1996). Most toluene is initially metabolized by side-chain hydroxylation to form benzyl alcohol, followed by oxidation to benzoic acid. The main CYP isozyme involved in the formation of benzyl alcohol is CYP2E1, although CYP2B1, CYP2B6, CYP2C6, CYP1A2, and CYP1A1 (in decreasing order) are also active. Most of the benzoic acid is then conjugated with glycine to form hippuric acid, although some can be conjugated with uridine-5'-diphosphate (UDP)-glucuronate to form the acyl-glucuronide. In both humans and rats, up to about 75–80% of inhaled toluene that is absorbed can be accounted for as hippuric acid in the urine. Much of the remaining toluene is exhaled unchanged. A very small portion (<1–5%) of absorbed toluene undergoes ring hydroxylation by CYP1A2, CYP2B2, or CYP2E1 to form 2,3- and 3,4-epoxide intermediates and subsequently ortho- or para-cresols, which are conjugated with sulfate or glucuronate (Baelum et al. 1993, Nakajima and Wang 1994; Nakajima et al. 1997; Tassaneeyakul et al. 1996). Other minor metabolites include S-benzyl mercapturic acid and S-p-toluylmercapturic acid, which are thought to be formed by a series of steps beginning with benzyl alcohol and 3,4-toluene expoxide, respectively (Angerer et al. 1998). The liver is expected to be the main site of toluene metabolism, based on the concentration of CYP isozymes in the liver relative to other tissues. Studies in rats indicate that the expression of hepatic CYP isozymes is influenced by various factors, including age, sex, and level of toluene exposure (Nakajima and Wang 1994).

As indicated above, studies with humans and laboratory animals indicate that following acute periods of inhalation exposure to toluene, absorbed toluene is excreted predominately in the urine as metabolites and, to a lesser extent, as nonmetabolized toluene in exhaled air (Lof et al. 1993; Ogata 1984; Tardif et al. 1998). For example, following a 2-hour exposure with light physical exercise to deuterium-labeled toluene at a concentration of 200 mg/m^3^ (53 ppm), an average 78% of retained label was excreted as urinary hippuric acid within 20 hours by a group of nine volunteers (Lof et al. 1993). A significant portion of absorbed toluene in this and other studies has been estimated to be exhaled as nonmetabolized toluene (7–20% of absorbed toluene) (Carlsson 1982; Leung and Paustenbach 1988; Lof et al. 1993). Analyses of kinetic data for toluene concentrations in blood, exhaled breath, or adipose tissue following inhalation exposure of humans and rats indicate that most absorbed toluene is rapidly eliminated from the body and that a smaller portion (that which gets into adipose tissues) is slowly eliminated (Leung and Paustenbach 1988; Lof et al. 1993; Pellizzari et al. 1992; Pierce et al. 1996, 1999; Rees et al. 1985). For example, using PBPK models, mean terminal half-lives of about 30–38 hours were calculated for changes in blood toluene concentrations between 50 and 100 hours after cessation of 2-hour inhalation exposures of male subjects to 50 ppm ^1^H_8_-toluene and 50 ppm ^2^H_8_-toluene (Pierce et al. 1996, 1999). During this terminal phase of disposition, >95% of toluene is expected to be in adipose tissue and the release of toluene from adipose tissues has been proposed to be the rate-limiting step (Pierce et al. 1999). Elimination half-lives ranged from about 12 to 65 hours in subcutaneous adipose tissue samples taken from 12 subjects at several times within 8 days of cessation of exposure to about 80 ppm toluene for four consecutive 30-minute periods, and increasing elimination half-lives were significantly correlated with increasing amounts of body fat (Carlsson and Ljungquist 1982).

PBPK models are available that describe the kinetics of toluene after inhalation exposure in humans (Fisher et al. 1997; Lapare et al. 1993; Pierce et al. 1996, 1999) and rats (DeJongh and Blaauboer 1996, 1997; Tardif et al. 1993b).

## B.2 Health Effects

The nervous system is the critical target of toluene toxicity following acute, intermediate, or chronic inhalation or oral exposure to toluene (ATSDR 2000). Effects on the human nervous system from inhaled toluene are well documented. Studies with volunteers under controlled acute (6–8 hours) exposure conditions indicate that subtle neurological impairment is detectable in most subjects at concentrations in the 75–150 ppm range (Andersen et al. 1983; Baelum et al. 1985; Echeverria et al. 1991; Guzelian et al. 1988; Iregren 1986; Rahill et al. 1996). Concentrations of 200–800 ppm can produce exhilaration and light-headedness, and, at higher acute exposure concentrations, intellectual, psychomotor, and neuromuscular abilities are obviously impaired followed by development of narcosis (EPA 1985; von Oettingen et al. 1942). Numerous case studies have associated chronic inhalation exposure to toluene at levels inducing narcosis and euphoria (estimated 4,000–12,000 ppm) with residual or permanent neurological damage as evidenced by abnormal electroencephalograms, structural changes in the brain, tremors, paranoid psychosis, recurrent hallucinations, and impaired speech, hearing, and vision (ATSDR 2000). Studies of workers repeatedly exposed to toluene in workplace air at concentrations ranging from about 30 to 150 ppm have found evidence for increased incidence of self-reported neurological symptoms, performance deficits in neurobehavioral tests, hearing loss, changes in visual-evoked brainstem potentials, and color vision impairment (Abbate et al. 1993; Boey et al. 1997; Foo et al. 1990; Morata et al. 1997; Orbaek and Nise 1989; Vrca et al. 1995, 1997a, 1997b; Yin et al. 1987; Zavalic et al. 1998a, 1998b, 1998c).

Supporting neurological effects data come from inhalation studies of toluene-exposed animals showing changes in behavior, hearing loss, and subtle changes in brain structure, electrophysiology, and levels of neurotransmitters (ATSDR 2000). For example, performance deficits in trained neuromuscular responses occurred in rats exposed concentrations as low as 125 ppm toluene for 4 hours (Kishi et al. 1988; Mullin and Krivanek 1982; Wood et al. 1983), changes in brain biochemical variables (e.g., dopamine levels, dopamine D2 receptor binding, changes in glial fibrillary acidic protein) were induced in rats exposed to concentrations as low as 50–80 ppm for 6–8 hours/day (API 1997; Hillefors-Bergllund et al. 1995; Ikeda et al. 1986; Little et al. 1998; von Euler et al. 1989, 1993, 1994), hearing loss occurred in rats exposed to concentrations as low as 700–1,000 ppm, 6–14 hours/day for 2–9 weeks (Campo et al. 1997, 1998; Johnson et al. 1988; Pryor and Rebert 1992; Pryor et al. 1984a, 1984b, 1991), and decreases in brain weight and phospholipid content occurred in rats continuously exposed to 320 ppm for 30 days (Kyrklund et al. 1987). Neurological effects observed in animals after acute- or intermediate-duration oral exposure include changed flash-evoked potentials in rats given single gavage doses of toluene as low as 250 mg/kg (Dyer et al. 1988), and changes in brain levels of several neurotransmitters (e.g., norepinephrine, dopamine, serotonin) in mice exposed to 5–105 mg/kg/day in drinking water for 28 days (Hsieh et al. 1990).

Toluene has caused respiratory tract irritation in humans following acute-duration inhalation exposure to concentrations above approximately 100 ppm, but there is little evidence for other adverse effects (ATSDR 2000). Studies of chronic toluene abusers or occupationally exposed humans have provided little evidence for serious liver damage due to inhaled toluene. Increases in liver weight (likely associated with microsomal enzyme induction), but no significant hepatic histological changes, were found in rats and mice following acute, intermediate, or chronic exposure to concentrations above 300 ppm (ATSDR 2000). The kidney may be a target of toluene toxicity following exposure to very high levels of toluene. Renal acidosis was observed in solvent abusers exposed to toluene, but the renal dysfunction usually reversed when exposure ceased, and the cases were frequently confounded by probable exposure to multiple solvents (ATSDR 2000). Kidney damage (e.g., renal tubular casts) was induced in rats after intermediate- and chronic-duration exposure to concentrations above 600 ppm (CIIT 1980; NTP 1990).

There is suggestive evidence that toluene may cause some reproductive problems, especially with repeated inhalation exposure during pregnancy to concentrations above 200 ppm (ATSDR 2000). Increased risks of spontaneous abortions were observed in women occupationally exposed to toluene, or wives of men similarly exposed (Lindbohm et al. 1992; Ng et al. 1992; Taskinen et al. 1989). However, interpretation of these results is limited due to small sample size evaluated, an inability to define accurate exposure levels, failure to account for all possible confounding variables, and the difficulty in validating self-reported data. Occupational exposure to increasing concentrations of toluene (8–111 ppm) has been associated with decreased plasma levels of the luteinizing hormone, follicle stimulating hormone and testosterone levels in males (Svensson et al. 1992a, 1992b). Studies in animals found some minor toluene-induced changes in male and female reproductive organs (e.g., decreased sperm count in male rats [Ono et al. 1995, 1996] and ultrastructural changes in antral follicles in ovary of female rats [Tap et al. 1996]), but no histological evidence of structural damage to the reproductive organs in rats and mice exposed orally for intermediate durations or by inhalation for intermediate or chronic durations (NTP 1990). No evidence for impaired reproductive performance was found in several assays (Ono et al. 1995, 1996; Smith 1983; Thiel and Chahoud 1997), including a 2-generation study of rats intermittently exposed to up to 2,000 ppm (API 1985), although gestational exposure to toluene caused increased fetal mortality in rats intermittently exposed to 2,000 ppm (Ono et al. 1995, 1996), and increased abortions in rabbits continuously exposed to 267 ppm but not 133 ppm (Ungvary and Tatrai 1985).

A number of reports of birth defects in children born to women who abused toluene or other organic solvents during pregnancy suggest that high-level (4,000–12,000 ppm) exposure to toluene during pregnancy can be toxic to the developing fetus, causing effects that included microcephaly, central nervous system dysfunction, growth deficiency, cranofacial and limb abnormalities, and reversible renal tubular acidosis (ATSDR 2000). Results from several inhalation exposure studies of animals indicate that exposure to levels of toluene that begin to produce maternal toxicity can cause fetal effects, including reduced fetal survival and retardation of growth and skeletal development (Courtney et al. 1986; Hudak and Ungvary 1978; Huntingdon Research Centre 1992a, 1992b; Ono et al. 1995; Thiel and Chahoud 1997; Ungvary and Tatrai 1985). No-effect levels in animals for toluene effects on standard developmental endpoints ranged from about 133–750 ppm. In animal studies of oral exposure during gestation, no developmental effects were observed in pregnant mice exposed to doses of ≥1,800 mg/kg/day (Seidenberg et al. 1986; Smith 1983), but exposure of pregnant rats to gavage doses of 650 mg/kg/day produced offspring with decreased body weights, delayed ossification, smaller brain volumes, and decreased forebrain myelination per cell compared with controls (Gospe and Zhou 1998; Gospe et al. 1996). Results from studies of neurobehavioral endpoints in rats following gestational exposure to toluene suggest that intermittent inhalation exposure to concentrations >1,200 ppm can impair offspring behavioral development (Jones and Balster 1997; Ono et al. 1995; Thiel and Chahoud 1997) and that drinking water exposure during gestation and lactation at doses of 106 mg/kg/day changes postweaning open-field locomotor activity in rat offspring (Kostas and Hotchin 1981).

Human and animal studies generally do not support a concern for the carcinogenicity of toluene. Eleven human epidemiology studies assessed toluene exposure as a possible risk factor for cancer (ATSDR 2000). Cancers of most sites were not significantly associated with toluene exposure in any study and there was weak consistency in the findings of those studies that did find association of a particular cancer type with toluene exposure. Three cohort studies involved workers occupationally exposed predominantly to toluene, whereas the remainder of the human studies primarily involved subjects exposed to mixtures of solvents including toluene (Antilla et al. 1998; ATSDR 2000; Svensson et al. 1990; Walker et al. 1993). The information from the human studies is inadequate to assess the carcinogenic potential of toluene, mainly because of the lack of consistent findings across the studies and the likelihood that many of the studied groups were exposed to multiple chemicals. Chronic bioassays in animals found no dose-related increased incidences of neoplastic lesions in rats or mice exposed by inhalation or in orally exposed rats (CIIT 1980; Maltoni et al. 1997; NTP 1990). Toluene was generally nongenotoxic in in vivo studies of exposed humans, in vitro microbial assays, and other in vitro test systems (ATSDR 2000).

## B.3 Mechanisms of Action

The mechanism by which acute exposure to toluene brings about neurological effects such as central nervous system depression and narcosis is generally thought to involve, at least in part, reversible interactions between toluene (the parent compound and not its metabolites) and components (lipids or proteins) of nervous system membranes (ATSDR 2000). Support of parent-material involvement comes from the observation that pretreatment of rats with phenobarbital increased the rate of in vivo toluene metabolism and shortened the time of recovery from narcosis from single intraperitoneal doses of toluene (Ikeda and Ohtsuji 1971). Other support for this hypothesis includes the transient nature of anesthesia from acute high level exposure to toluene and the rapidity with which toluene-induced changes in brain biochemical variables can be measured (Korpela and Tahti 1988; Lebel and Schatz 1988, 1989, 1990; Rea et al. 1984). On a molecular level, the acute anaesthetic actions of toluene and other agents have been postulated to involve intercalation of toluene into the lipid bilayer of nerve membranes and/or reversible interactions with proteins in the membrane (Franks and Lieb 1985, 1987).

Clinically obvious neurological impairment (e.g., gait and speech abnormalities) and brain atrophy have been observed in several cases of chronic toluene-inhalation abuse. Magnetic resonance imagery (MRI) of the brain of solvent abusers (Filley et al. 1990; Rosenberg et al. 1988a, 1988b) suggest preferential atrophy in lipid-rich regions of the brain (ATSDR 2000). The MRI changes may be related to lipid compositional changes in the white matter, since these regions are more lipid-rich than gray matter (Ameno et al. 1992). The observations are consistent with a hypothesis that chronic exposure to high concentrations of toluene brings about structural changes in the brain related to lipid compositional changes (ATSDR 2000). Supporting evidence for this hypothesis includes altered phospholipid composition of brain synaptosomes, decreased phospholipid concentrations in the cerebral cortex, and decreased number of neurons in the hippocampus in toluene-exposed rats (Korbo et al. 1996; Kyrklund et al. 1987; Lebel and Schatz 1988, 1989, 1990). It is uncertain if toluene-induced changes in membrane phospholipid content may be caused by increased breakdown of phospholipids or inhibition of synthesis.

## B.4 Health Guidelines

ATSDR (2000) derived an acute-duration inhalation MRL of 1 ppm for toluene based on a NOAEL of 40 ppm for subjective neurological effects (headaches, dizziness, and feelings of intoxication) and eye and nose irritation in humans (Andersen et al. 1983) and an uncertainty factor of 10 (to account for human variability). Volunteers were experimentally exposed to toluene 6 hours/day for 4 consecutive days.

ATSDR (2000) did not derive an intermediate-duration inhalation MRL for toluene due to lack of suitable data, but the chronic inhalation MRL would also be protective for intermediate-duration exposures.

ATSDR (2000) derived a chronic-duration inhalation MRL of 0.08 ppm for toluene based on a LOAEL of 35 ppm for neurological effects (color vision impairment) in humans (Zavalic et al. 1998b) and an uncertainty factor of 100 (10 for use of a LOAEL and 10 for human variability). Workers were occupationally exposed to benzene for an average of 16 years.

ATSDR (2000) derived an acute-duration oral MRL of 0.8 mg/kg for toluene based on a LOAEL of 250 mg/kg/day for neurological effects (decreased flash-evoked potential) in rats (Dyer et al. 1988) and an uncertainty factor of 300 (3 for the use of a minimal LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability). The animals were administered a single dose of toluene by gavage.

ATSDR (2000) derived an intermediate-duration oral MRL of 0.02 mg/kg/day for toluene based on a LOAEL of 5 mg/kg/day for neurological effects (regional brain increases in monoamine neurotransmitters) in mice (Hsieh et al. 1990) and an uncertainty factor of 300 (3 for the use of a minimal LOAEL, 10 for extrapolation from animals to humans, and 10 for human variability). The animals were exposed to toluene in drinking water for 28 days.

ATSDR (2000) did not derive a chronic-duration oral MRL for toluene due to lack of suitable data.

The EPA IRIS database lists an RfD and an RfC for toluene (IRIS 2001). The RfD is based on a NOAEL of 312 mg/kg/day (converted to 223 mg/kg/day) for changes in liver and kidney weights in rats (NTP 1990) and an uncertainty factor of 1,000 (applied to account for inter- and intraspecies extrapolations, for subchronic-to-chronic extrapolation, and for limited reproductive and developmental toxicity data). The animals were exposed to toluene in corn oil by gavage 5 days/week for 13 weeks.

The EPA RfC for toluene is based on a LOAEL of 88 for neurological effects in humans (Foo et al. 1990) and an uncertainty factor of 300 (10 for use of a LOAEL, 10 for human variability, and 3 for database deficiencies) (IRIS 2001). Workers were occupationally exposed to toluene for an average of 5.7 years.

ACGIH (2001) recommends a TLV-TWA of 50 ppm for toluene based on central nervous system effects (reports of headache and irritation in humans associated with 4–6 hours of continuous inhalation of toluene).

The NTP (2001) has not listed toluene as a known or anticipated human carcinogen. EPA determined that toluene is not classifiable as to carcinogenicity (Category D) based on no human data and inadequate animal data (IRIS 2001). IARC (1999a) concluded that toluene is not classifiable as to its carcinogenicity (Group 3) to humans based on inadequate evidence in humans and evidence suggesting lack of carcinogenicity in animals.

## B.5 References

Abbate C, Garganey C, Munao F, 1993. Neurotoxicity induced by exposure to toluene. An electrophysiologic study. Int Arch Occup Environ Health 64:389–392. (As cited in ATSDR 2000.)8458653
ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Ameno K, Kiriu T, Fuke C, 1992. Regional brain distribution of toluene in rats and in human autopsy. Arch Toxicol 66:153–156. (As cited in ATSDR 2000.)1605733
Andersen I, Lundqvist GR, Molhave L, 1983. Human response to controlled levels of toluene in six-hour exposures. Scand J Work Environ Health 9:405–418. (As cited in ATSDR 2000.)6673099
Angerer J, Schildbach M, Kramer A. 1998. S-p-toluylmercapturic acid in the urine of workers exposed to toluene: A new biomarker for toluene exposure. Arch Toxicol 72(2):119–23. (As cited in ATSDR 2000.)9456085
Antilla A, Pukkala E, Riala R, 1998. Cancer incidence among Finnish workers exposed to aromatic hydrocarbons. Int Arch Occup Environ Health 71:187–193. (As cited in ATSDR 2000.)9591160
API. 1985. Two-generation reproduction/fertility study on a petroleum-derived hydrocarbon (toluene) Vol. 1. Washington, DC: American Petroleum Institute. (As cited in ATSDR 2000.)
API. 1997. Brain glial fibrillary acidic protein (GFAP) as a marker of neurotoxicity during inhalation exposure to toluene. Washington, DC: American Petroleum Institute. API Publication Number 4647. (As cited in ATSDR 2000.)
ATSDR. 2000. Toxicological profile for toluene. Atlanta, GA: U.S. Department of Health and Human Services, Public Health Service, Agency for Toxic Substances and Disease Registry.
Baelum J, Andersen I, Lundqvist GR, 1985. Response of solvent-exposed printers and unexposed controls to six-hour toluene exposure. Scand J Work Environ Health 11:271–280. (As cited in ATSDR 2000.)4059890
Baelum J, Molhave L, Honore Hansen S, 1993. Hepatic metabolism of toluene after gastrointestinal uptake in humans. Scand J Work Environ Health 19(1):55–62. (As cited in ATSDR 2000.)8465173
Benoit FM, Davidson WR, Lovett AM, 1985. Breath analysis by API/MS human exposure to volatile organic solvents. Int Arch Occup Environ Health 55:113–120. (As cited in ATSDR 2000.)3988355
Bergman K. 1979. Application and results of whole-body autoradiography in distribution studies of organic solvents. CRC Crit Rev Toxicol 12(1):59–118. (As cited in ATSDR 2000.)
Boey KW, Foo SC, Jeyaratnam J. 1997. Effects of occupational exposure to toluene: A neuropsychological study on workers in Singapore. Ann Acad Med Singapore 26(2):84–7. (As cited in ATSDR 2000.)
Campo P, Lataye R, Cossec B, 1997. Toluene-induced hearing loss: A mid-frequency location of the cochlear lesions. Neurotoxicol Teratol 19(2):129–40. (As cited in ATSDR 2000.)9136129
Campo P, Lataye R, Cossec B, 1998. Combined effects of simultaneous exposure to toluene and ethanol on auditory function in rats. Neurotoxicol Teratol 20(3):321–332. (As cited in ATSDR 2000.)9638690
Carlsson A. 1982. Exposure to toluene: Uptake, distribution and elimination in man. Scand J Work Environ Health 8:43–55. (As cited in ATSDR 2000.)
Carlsson A, Ljungquist E. 1982. Exposure to toluene: Concentration in subcutaneous adipose tissue. Scand J Work Environ Health 8:56–62. (As cited in ATSDR 2000.)7134923
CIIT. 1980. A 24 month inhalation toxicology study in Fischer-344 rat exposed to atmospheric toluene. Executive Summary and Data Tables. Research Triangle Park, NC: Chemical Industry Institute of Toxicology. October 15, 1980. (As cited in ATSDR 2000.)
Courtney KD, Andrews JE, Springer J, 1986. A perinatal study of toluene in CD-1 mice. Fundam Appl Toxicol 6:145–154. (As cited in ATSDR 2000.)3710019
DeJongh J, Blaauboer BJ. 1996. Simulation of toluene kinetics in the rat by a physiologically based pharmacokinetic model with application of biotransformation parameters derived independently in vitro and in vivo. Fund Appl Toxicol 32(2):260–8. (As cited in ATSDR 2000.)
DeJongh J, Blaauboer BJ. 1997. Evaluation of in vitro-based simulations of toluene uptake and metabolism in rats. Toxicol in Vitro 11:485–489. (As cited in ATSDR 2000.)20654339
Dutkiewicz T, Tyras H. 1968. Skin absorption of toluene, styrene and xylene by man. Br J Ind Med 25:243. (As cited in ATSDR 2000.)5663430
Dyer RS, Bercegeay MS, Mayo LM. 1988. Acute exposures to p-xylene and toluene alter visual information processing. Neurotoxicol Teratol 10:147–153. (As cited in ATSDR 2000.)3398823
Echeverria D, Fine L, Langolf G, 1991. Acute behavioural effects of toluene and ethanol in human subjects. Br J Ind Med 48:750–761. (As cited in ATSDR 2000.)1954153
EPA. 1985. Drinking water criteria document for toluene. Washington, DC: U.S. Environmental Protection Agency, Office of Drinking Water. ECAO-CIN-408. EPA 600/x-84–188. PB 86–117975. (As cited in ATSDR 2000.)
Filley CM, Heaton RK, Rosenberg NL. 1990. White matter dementia in chronic toluene abuse. Neurology 40:532–534. (As cited in ATSDR 2000.)2314597
Fischer J, Mahle D, Bankston L, 1997. Lactational transfer of volatile chemicals in breast milk. Am Ind Hyg Assoc J 58(6):425–431.(As cited in ATSDR 2000.)9183837
Foo SC, Jeyaratnam J, Koh D. 1990. Chronic neurobehavioural effects of toluene. Br J Ind Med 47:480–484. (As cited in ATSDR 2000.)2383518
Franks NP, Lieb WR. 1985. Mapping of general anaesthetic target sites provides a molecular basis for cutoff effects. Nature 316: 349–351.4022125
Franks NP, Lieb WR. 1987. Anaesthetics on the mind. Nature 328:113–114.3600786
Gospe SM, Zhou SS. 1998. Toluene abuse embryopathy: Longitudinal neurodevelopment effects of prenatal exposure to toluene in rats. Reprod Toxicol 12(2):119–126. (As cited in ATSDR 2000.)9535505
Gospe SM Jr, Zhou SS, Saeed DB 1996. Development of a rat model of toluene-abuse embryopathy. Pediatr Res 40(1):82–87. (As cited in ATSDR 2000.)8798251
Gut I, Terelius Y, Frantík E, 1993. Exposure to various benzene derivatives differently induces cytochromes P450 2B1 and P450 2E1 in rat liver. Arch Toxicol 67:237–243.8517779
Guzelian P, Mills S, Fallon HJ. 1988. Liver structure and function in print workers exposed to toluene. J Occup Med 30(10):791–796. (As cited in ATSDR 2000.)3230426
Hillefors-Berglund M, Liu Y, von Euler G. 1995. Persistent, specific and dose-dependent effects of toluene exposure on dopamine D2 agonist binding in the rat caudate-putamen. Toxicology 100:185–94. (As cited in ATSDR 2000.)7624876
Hjelm EW, Naslund PH, Wallen M. 1988. Influence of cigarette smoking on the toxicokinetics of toluene in humans. J Toxicol Environ Health 25:155–163. (As cited in ATSDR 2000.)3172270
Hsieh GC, Sharma RP, Parker RD, 1990. Evaluation of toluene exposure via drinking water on levels of regional brain biogenic monoamines and their metabolites in CD-1 mice. Ecotoxicol Environ Saf 20:175–184. (As cited in ATSDR 2000.)1980457
Hudak A, Ungvary G. 1978. Embryotoxic effects of benzene and its methyl derivatives: Toluene, xylene. Toxicology 11:55–63. (As cited in ATSDR 2000.)705804
Huntingdon Research Centre. 1992a. A preliminary study of the effect of toluene on pregnancy of the rat (inhalation exposure). Huntingdon, Cambridgeshire, England: Huntingdon Research Centre, Ltd. APT 1/91309. (As cited in ATSDR 2000.)
Huntingdon Research Centre. 1992b. Toluene: Effect on pregnancy of the rat by inhalation (status report). Huntingdon, Cambridgeshire, England: Huntingdon Research Centre, Ltd. APT 2/91279. (As cited in ATSDR 2000.)
IARC. 1999a. IARC monographs on the evaluation of carcinogenic risks to humans: Re-evaluation of some organic chemicals, hydrazine and hydrogen peroxide. Volume 71. Part 2. Lyon, France: World Health Organization, International Agency for Research on Cancer, 829–864.
Ikeda M, Ohtsuji H. 1971. Phenobarbital-induced protection against toxicity of toluene and benzene in the rat. Toxicol Appl Pharmacol 20:30–43. (As cited in ATSDR 2000.)5110825
Ikeda M, Koizumi A, Kasahara M, 1986. Combined effects of n-hexane and toluene on norepinephrine and dopamine levels in rat brain tissues after long-term exposure. Bull Environ Contam Toxicol 36:510–517. (As cited in ATSDR 2000.)3697527
Iregren A. 1986. Subjective and objective signs of organic solvent toxicity among occupationally exposed workers. Scand J Work Environ Health 12:469–475. (As cited in ATSDR 2000.)3787219
IRIS. 2001. Toluene. Integrated Risk Information System, U.S. Environmental Protection Agency. http//:www.epa.gov/iris/subst/0118.htm (http://www.epa.gov/iris/subst/0118.htm).
Johnson AC, Juntunen L, Nylen P, 1988. Effect of interaction between noise and toluene on auditory function in the rat. Acta Otolaryngol 101:56–63. (As cited in ATSDR 2000.)
Jones HE, Balster RL. 1997. Neurobehavioral consequences of intermittent prenatal exposure to high concentrations of toluene. Neurotoxicol Teratol 19(4):305–313. (As cited in ATSDR 2000.)9253009
Kishi R, Harabuchi I, Ikeda T, 1988. Neurobehavioral effects and pharmacokinetics of toluene in rats and their relevance to man. Br J Ind Med 45:396–408. (As cited in ATSDR 2000.)3395575
Korbo L, Ladefoged O, Lam HR, 1996. Neuronal loss in hippocampus in rats exposed to toluene. Neurotoxicology 17(2):359–66. (As cited in ATSDR 2000.)8856732
Korpela M, Tahti H. 1988. The effect of in vitro and in vivo toluene exposure on rat erythrocyte and synaptosome membrane integral enzymes. Pharmcol Toxicol 63:30–32. (As cited in ATSDR 2000.)
Kostas J, Hotchin J. 1981. Behavioral effects of low-level perinatal exposure to toluene in mice. Neurobehav Toxicol Teratol 3:467–469. (As cited in ATSDR 2000.)7335140
Kyrklund T, Kjellstrand P, Haglid K. 1987. Brain lipid changes in rats exposed to xylene and toluene. Toxicology 5:123–133. (As cited in ATSDR 2000.)
Lam CW, Galen TJ, Boyd JF, 1990. Mechanism of transport and distribution of organic solvents in blood. Toxicol Appl Pharmacol 104:117–129. (As cited in ATSDR 2000.)2360202
Lapare S, Tardif R, Brodeur J. 1993. Effect of various exposure scenarios on the biological monitoring of organic solvents in alveolar air: I. Toluene and m-xylene. Int Arch Occup Environ Health 64(8):569–80.8314616
LeBel CP, Schatz RA. 1988. Toluene-induced alterations in rat synaptosomal membrane composition and function. J Biochem Toxicol 3:279–293. (As cited in ATSDR 2000.)3236335
LeBel CP, Schatz RA. 1989. Effect of toluene on rat synapsomal phospholipid methylation and membrane fluidity. Biochem Pharmacol 38(22):4005–4011. (As cited in ATSDR 2000.)2597181
LeBel CP, Schatz RA. 1990. Altered synaptosomal phospholipid metabolism after toluene: Possible relationship with membrane fluidity, Na+, K+-adewnosine triphosphatase and phospholipid methylation. J Pharmacol Exp Ther 253(3):1189–1197. (As cited in ATSDR 2000.)2162949
Leung H-W, Paustenbach DJ. 1988. Application of pharmacokinetics to derive biological exposure indexes from threshold limit values. Am Ind Hyg Assoc J 49(9):445–450. (As cited in ATSDR 2000.)3177223
Lindbohm L, Taskinen H, Kyyronen P, 1992. Effects of parental occupational exposure to solvents and lead on spontaneous abortion. Scand J Work Environ J Health 18:37–39. (As cited in ATSDR 2000.)
Little AR, Gong Z, Singh U, 1998. Decreases in brain glial fibrillary acidic protein (GFAP) are associated with increased serum corticosterone following inhalation exposure to toluene. Neurotoxicology 19(4–5):739–748. (As cited in ATSDR 2000.)9745935
Lof A, Hjelm EW, Colmsjo A, 1993. Toxicokinetics of toluene and urinary excretion of hippuric acid after human exposure to ^2^H_8_-toluene. Br J Ind Med 50:55–59. (As cited in ATSDR 2000.)8431392
Maltoni C, Ciliberti A, Pinto C, 1997. Results of long-term experimental carcinogenicity studies of the effects of gasoline, correlated fuels, and major gasoline aromatics on rats. Ann N Y Acad Sci 837:15–52. (As cited in ATSDR 2000.)9472329
Morata TC, Fiorini AC, Fischer FM, 1997. Toluene-induced hearing loss among rotogravure printing workers. Scand J Work Environ Health 23(4): 289–98. (As cited in ATSDR 2000.)9322820
Mullin LS, Krivanek ND. 1982. Comparison of unconditioned reflex and conditioned avoidance tests in rats exposed by inhalation to carbon monoxide, 1,1,1-trichloroethane, toluene or ethanol. Neurotoxicology 3:126–137. (As cited in ATSDR 2000.)6890184
Nakajima T, Wang RS. 1994. Induction of cytochrome P450 by toluene. Int J Biochem 12:1333–1340.
Nakajima T, Wang R-S, Elovaara E, 1991. Monoclonal antibody-directed characterization of cytochrome P-450 isozymes responsible for toluene metabolism in rat liver. Biochem Pharmacol 41(3):395–404. (As cited in ATSDR 2000.)1994898
Nakajima T, Wang R-S, Elovaara E, 1992a. A comparative study on the contribution of cytochrome P450 isozymes to metabolism of benzene, toluene and trichloroethylene in rat liver. Biochem Pharmacol 43:251–257.1739413
Nakajima T, Wang R-S, Elovaara E, 1993. Cytochrome P450-related differences between rats and mice in the metabolism of benzene, toluene and trichloroethylene in liver microsomes. Biochem Pharmacol 45(5):1079–1085.8461037
Nakajima T, Wang R-S, Elovaara E, 1997. Toluene metabolism by cDNA-expressed human hepatic cytochrome P-450. Biochemical Pharmacology 53(3):271–277. (As cited in ATSDR 2000.)9065730
Nakajima T, Wang R-S, Katakura Y, 1992b. Sex-, age- and pregnancy-induced changes in the metabolism of toluene and trichloroethylene in rat liver in relation to the regulation of cytochrome P45011E1 and P45011C11 content. J Pharmacol Exp Ther 261(3):869–874. (As cited in ATSDR 2000.)1602390
Ng TP, Foo SC, Yoong T. 1992. Risk of spontaneous abortion in workers exposed to toluene. Br J Ind Med 49:804–808. (As cited in ATSDR 2000.)1463682
NTP. 1990. National Toxicology Program technical report series toxicology and carcinogenesis studies of toluene (CAS No. 108–88-3) in F344/N rats and B6C3F mice (inhalation studies). Research Triangle Park, NC: U.S. Environmental Protection Agency, Department of Health and Human Services. No. 371. PB90–256371. (As cited in ATSDR 2000.)
NTP. 2001. Ninth report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. June 2001.
Ogata M. 1984. Estimation of solvent concentrations in ambient air from urinary metabolite levels of workers exposed to solvents. Ind Health 22:319–324. (As cited in ATSDR 2000.)6526705
Ono A, Sekita K, Ogawa Y, 1996. Reproductive and developmental toxicity studies of toluene: II. Effects of inhalation exposure on fertility rats. J Environ Pathol Toxicol Oncol 15(1):9–20. (As cited in ATSDR 2000.)9037260
Ono A, Sekita K, Ohno K, 1995. Reproductive and developmental toxicity studies of toluene: I. Teratogenicity study of inhalation exposure in pregnant rats. J Toxicol Sci 20(2):109–34. (As cited in ATSDR 2000.)7473890
Orbaek P, Nise G. 1989. Neurasthenic complaints and psychometric function of toluene-exposed rotogravure printers. Am J Ind Med 16:67–77. (As cited in ATSDR 2000.)2750752
Pierce CH, Dills RL, Morgan MS, 1996. Interindividual differences in ^2^H_8_-toluene toxicokinetics assessed by semi-empirical physiologically based model. Toxicol Appl Pharmacol 139(1):49–61. (As cited in ATSDR 2000.)8685908
Pierce CH, Lewandowski TA, Dills RL, 1999. A comparison of 1H8-toluene toxicokinetics in men. Xenobiotica 29(1):93–108. (As cited in ATSDR 2000.)10078842
Pellizzari ED, Wallace LA, Gordon SM. 1992. Elimination kinetics of volatile organics in humans using breath measurements. J Expo Anal Environ Epidemiol 2(3):341–55. (As cited in ATSDR 2000.)1422163
Pryor GT, Rebert CS. 1992. Interactive effects of toluene and hexane on behavior and neurophysiologic responses in Fischer-344 rats. Neurotoxicology 13:225–234. (As cited in ATSDR 2000.)1508424
Pryor GT, Dickinson J, Feeney E, 1984a. Hearing loss in rats first exposed to toluene as weanlings or as young adults. Neurobehav Toxicol Teratol 6:223–238. (As cited in ATSDR 2000.)6493426
Pryor GT, Rebert CS, Dickinson J, 1984b. Factors affecting toluene-induced ototoxicity in rats. Neurobehav Toxicol Teratol 6:223–238. (As cited in ATSDR 2000.)6493426
Pryor GT, Rebert CS, Kassay K, 1991. The hearing loss associated with exposure to toluene is not caused by metabolite. Brain Res Bull 27:109–113. (As cited in ATSDR 2000.)1933422
Pyykko K, Tahti H, Vapaatalo H. 1977. Toluene concentrations in various tissues of rats after inhalation and oral administration. Arch Toxicol 38:169–176. (As cited in ATSDR 2000.)578720
Rahill AA, Weiss B, Morrow PE, 1996. Human performance during exposure to toluene. Aviat Space Environ Med 67(7):640–7. (As cited in ATSDR 2000.)8830943
Rea TM, Nash JF, Zabik JE, 1984. Effects of toluene inhalation on brain biogenic amines in the rat. Toxicology 31:143–150. (As cited in ATSDR 2000.)6740691
Rees DC, Wood RW, McMormick JP, 1985. Toxicokinetics of toluene in the rat. Scand J Work Environ Health 11:301–306. (As cited in ATSDR 2000.)4059892
Rosenberg NL, Kleinschmidt-Demasters BK, Davis KA, 1988a. Toluene abuse causes diffuse central nervous system white matter changes. Ann Neurol 23(6):611–614. (As cited in ATSDR 2000.)3408242
Rosenberg NL, Spitz MC, Filley CM, 1988b. Central nervous system effects of chronic toluene abuse clinical, brainstem evoked response and magnetic resonance imaging studies. Neurotoxicol Teratol 10:489–495. (As cited in ATSDR 2000.)3247003
Seidenberg JM, Anderson DG, Becker RA. 1986. Validation of an in vivo developmental toxicity screen in the mouse. Teratogenesis Carcinogen Mutagen 6:361–374. (As cited in ATSDR 2000.)
Smith KN. 1983. Determination of the reproductive effects in mice of nine selected chemicals. Bioassay Systems Corporation. NIOSH Contract No. 210–81-6011. BSC Project No. 10867. (As cited in ATSDR 2000.)
Svensson B-G, Nise G, Englander V, 1990. Deaths and tumours among rotogravure printers exposed to toluene. Br J Ind Med 47:372–379. (As cited in ATSDR 2000.)2378814
Svensson B-G, Nise G, Erfurth EM, 1992a. Hormone status in occupational toluene exposure. Am J Ind Med 22:99–107. (As cited in ATSDR 2000.)1415282
Svensson B-G, Nise G, Erfurth EM, 1992b. Neuroendocrine effects in printing workers exposed to toluene. Br J Ind Med 49:402–408. (As cited in ATSDR 2000.)1606026
Tap O, Solmaz S, Polat S, 1996. The effect of toluene on the rat ovary: An ultrastructural study. J Submicrosc Cytol Pathol 28(4):553–8. (As cited in ATSDR 2000.)8933738
Tardif R, Lapare S, Krishnan K, 1993b. Physiologically based modeling of the toxicokinetic interaction between toluene and m-xylene in the rat. Toxicol Appl Pharmacol 120:266–273. (As cited in ATSDR 2000.)8511796
Tardif R, Truchon G, Brodeur J. 1998. Comparison of hippuric acid and o-cresol in urine and unchanged toluene in alveolar air for the biological monitoring of exposure to toluene in human volunteers. Appl Occup Environ Hyg 13(2):127–132.
Taskinen H, Anttila A, Lindbohm L, 1989. Spontaneous abortions and congenital malformations among the wives of men occupationally exposed to organic solvents. Scand J Work Environ Health 15:345–352. (As cited in ATSDR 2000.)2799322
Tassaneeyakul W, Birkett DJ, Edwards JW, 1996. Human cytochrome P450 isoform specificity in the regioselective metabolism of toluene and o-, and p-xylene. J Pharmacol Exp Ther 276(1):101–108.8558417
Thiel R, Chahoud I. 1997. Postnatal development and behaviour of Wistar rats after prenatal toluene exposure. Arch Toxicol 71(4):258–65. (As cited in ATSDR 2000.)9101043
Tsuruta H. 1989. Skin absorption of organic solvent vapors in nude mice in vivo. Ind Health 27:37–47.2745160
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and its alkyl derivatives in mice, rats and rabbits. Arch Toxicol (Suppl)8:425–430. (As cited in ATSDR 2000.)
von Euler G, Fuxe K, Hansson T, 1989. Persistent effects of neonatal toluene exposure on regional brain catecholamine levels and turnover in the adult male rat. Toxicology 54:1–16. (As cited in ATSDR 2000.)2916239
von Euler G, Ogren S-O, Eneroth P, 1994. Persistent effects of 80 ppm toluene on dopamine-regulated locomotor activity and prolactin secretion in the male rat. Neurotoxicology 15(3):621–4. (As cited in ATSDR 2000.)7854597
von Euler G, Ogren S-O, Li XM, 1993. Persistent effects of subchronic toluene exposure on spatial learning and memory, dopamine-mediated locomotor activity and dopamine D_2_ against binding in the rat. Toxicology 77:223–232. (As cited in ATSDR 2000.)8096348
von Oettingen WF, Neal PA, Donahue DD, 1942. The toxicity and potential dangers of toluene with special reference to its maximal permissible concentration. U.S. Public Health Service Publication Health Bull No. 279:50. (As cited in ATSDR 2000.)
Vrca A, Bozicevic D, Bozikov V, 1997a. Brain stem evoked potentials and visual evoked potentials in relation to the length of occupational exposure to low levels of toluene. Acta Medica Croatica 51:215–219. (As cited in ATSDR 2000.)9473801
Vrca A, Bozicevic D, Karacic V, 1995. Visual evoked potentials in individuals exposed to long-term low concentrations of toluene. Arch Toxicol 69(5):337–40. (As cited in ATSDR 2000.)7654139
Vrca A, Karacic V, Bozicevic D, 1997b. Cognitive evoked potentials VEP P300 in persons occupationally exposed to low concentrations of toluene. Arh Hig Rada Toksikol 48: 277–285. (As cited in ATSDR 2000.)9501630
Walker JT, Bloom TF, Stern FB, 1993. Mortality of workers employed in shoe manufacturing. Scand J Work Environ Health 19:89–95. (As cited in ATSDR 2000.)8316784
Wood RW, Rees DC, Laties VG. 1983. Behavioral effects of toluene are modulated by stimulus control. Toxicol Appl Pharmacol 68:462–472. (As cited in ATSDR 2000.)6857679
Yin S, Li G, Hu Y, 1987. Symptoms and signs of workers exposed to benzene, toluene or the combination. Ind Health 25:113–130.3679888
Zavalic M, Mandic Z, Turk R, 1998a. Assessment of colour vision impairment in male workers exposed to toluene generally above occupational exposure limits. Occup Med 48(3):175–180. (As cited in ATSDR 2000.)
Zavalic M, Mandic Z, Turk R, 1998b. Qualitative assessment of color vision impairment in workers exposed to toluene. Am J Ind Med 33(3): 297–304. (As cited in ATSDR 2000.)9481429
Zavalic M, Mandic Z, Turk R, 1998c. Qualitative color vision impairment in toluene-exposed workers. Int Arch Occup Environ Health 71:194–200. (As cited in ATSDR 2000.)9591161