# Appendix A Background Information for Benzene

This appendix summarizes information on the toxicokinetics, health effects, mechanisms of action, and health guidelines for benzene. The summaries are mainly based on information presented in the ATSDR (1997) toxicological profile for benzene and therefore do not represent reviews of the primary literature. The chemical structure for benzene is included in Appendix E.

## A.1 Toxicokinetics

Benzene is rapidly but incompletely absorbed by humans and animals following inhalation exposure (ATSDR 1997). Results of several studies indicate that average respiratory uptake is approximately 50% in humans. For example, in a study of 23 subjects who inhaled 47–110 ppm benzene for 2–3 hours, absorption was 70–80% during the first 5 minutes of exposure, but subsequently decreased to about 50% (range, 20–60%) by 1 hour (Srbova et al. 1950). Respiratory uptake was approximately 47% in six subjects exposed to 52–62 ppm benzene for 4 hours (Nomiyama and Nomiyama 1974), and 52 and 48% in three subjects exposed to 1.6 or 9.4 ppm, respectively, for 4 hours (Pekari et al. 1992). In rodents, the extent of uptake increased linearly with concentration for exposures up to approximately 200 ppm (ATSDR 1997). At concentrations >200 ppm, zero-order kinetics were observed (i.e., uptake became nonlinear, indicating saturation of the metabolic capacity). The percentage of inhaled benzene that was absorbed and retained during a 6-hour exposure period decreased from 33 to 15% in rats and from 50 to 10% in mice when the exposure concentration was increased from about 10 to 1,000 ppm (Sabourin et al. 1987). Mice and rats have different absorption characteristics in that the cumulative inhaled dose in mice was greater than that in rats (Eutermoser et al. 1986; Sabourin et al. 1987).

Quantitative oral absorption data are not available for benzene in humans. Oral doses of benzene are extensively absorbed in animals (generally >90%), although benzene was administered in oil in many oral studies to assure predictable solubility and dose concentration control (ATSDR 1997; Cornish and Ryan 1965; Parke and Williams 1953a, 1953b; Sabourin et al. 1987). One of the studies showed that gastrointestinal absorption was >97% in rats and mice when the animals were treated with benzene by gavage at doses 0.5–150 mg/kg (Sabourin et al. 1987). Dermal absorption of benzene is low in humans and animals. Approximately 0.05% of an applied dose (0.0026 mg/cm^2^) was determined in one human study (Franz 1984), and another estimated a dermal absorption rate of approximately 0.4 mg/cm^2^/hour under conditions of complete saturation (35–43 cm^2^ of skin was exposed to approximately 0.06 g/cm^2^ of liquid benzene for 1.25–2 hours) (Hanke et al. 1961). Animal studies found that dermal absorption was <1% following a single direct application of liquid benzene to Rhesus monkeys, minipigs, and hairless mice (Franz 1984; Maibach and Anjo 1981; Susten et al. 1985). Absorbed benzene is widely distributed to tissues, with the relative uptake dependent on the perfusion rate of the tissue by blood, and the total potential uptake dependent on fat content and metabolism (ATSDR 1997; Sato et al. 1975; Tauber 1970).

The metabolism and elimination of benzene appear to be qualitatively similar in humans and animals (ATSDR 1997; Henderson et al. 1989; Sabourin et al. 1988). Benzene is initially metabolized by cytochrome P-450-dependent mixed function oxidases primarily in the liver via several toxification and detoxification (via conjugation) pathways. Several cytochrome P-450 isozymes are involved in the metabolism of benzene, although the predominant form is CYP2E1 (Gut et al. 1993; Nakajima et al. 1993). The first metabolic step is the formation of the epoxide benzene oxide. This is followed by two toxification pathways, one involving ring hydroxylation and the second involving ring opening, resulting in the formation of putative toxic metabolites (ATSDR 1997; Henderson et al. 1989). In the first pathway involving ring hydroxylation, opening of the epoxide ring is followed by aromatization resulting in formation of phenol. Phenol is further converted into hydroquinone, which is oxidized to benzoquinone. The conjugates formed from hydroquinone (hydroquinone glucuronide and hydroquinone sulfate) are markers for this toxification pathway leading to benzoquinone. Phenol can also be metabolized to catechol and trihydroxy benzene. Metabolism of benzene oxide leads to the formation of benzene dihydrodiol. Catechol can also be formed from benzene dihydrodiol via metabolism by cytosolic dehydrogenases (Henderson et al. 1989). The second pathway involving ring-opening leads to the formation of muconic acid, apparently via the precursor muconic dialdehyde.

There are two detoxification pathways. One detoxification pathway leads to the formation of mercapturic acid via glutathione conjugates of benzene oxide, which are subsequently metabolized to prephenyl mercapturic acid and phenyl mercapturic acid and eliminated by biliary excretion (ATSDR 1997; Henderson et al. 1989; Sabourin et al. 1987; Schrenk et al. 1992). The major portion of benzene oxide is nonenzymatically rearranged to phenol. The second detoxification pathway involves the formation of water-soluble urinary metabolites, which are glucuronide or sulfate conjugates of phenol. Further metabolites of phenol and benzene dihydrodiol (e.g., catechol, hydroquinone, and trihydroxy benzene) are excreted as sulfate or glucuronide conjugates and are also considered detoxification products.

Although the metabolism of benzene occurs primarily in the liver, studies in rats and mice indicate that a small amount is metabolized independently of the liver in the bone marrow, the site of characteristic benzene toxicity (Ganousis et al. 1992; Irons et al. 1980). It is believed that biotransformation is essential for benzene-induced bone marrow damage, but it is unclear whether benzene is activated in the marrow, activated elsewhere and transported to the marrow, or metabolized in the liver and the metabolites activated in the marrow (ATSDR 1997). Benzene has been found to stimulate its own metabolism (Arinc et al. 1991; Gonasun et al. 1973; Saito et al. 1973). Differences in species, routes of exposure, and dosing regimens affect the disposition and metabolic fate of benzene (Sabourin et al. 1987, 1988, 1989a, 1989b, 1992). Benzene metabolism (both total and amounts of individual metabolites) is dose-dependent in all species studies thus far, including humans (ATSDR 1997). At low doses, more of the benzene is converted to putative toxic metabolites than at high doses. At high doses, benzene inhibits phenol metabolism to hydroquinone, apparently through competition for a common site on the CYP2E1 isozyme to which hydroquinone and catechol also bond. The effect that dose and species can have on the metabolism of benzene is illustrated by a study in which rats and mice were administered benzene by gavage at doses of 0.5–150 mg/kg (Sabourin et al. 1987). At doses below 15 mg/kg, >90% of the benzene was metabolized, while at doses above 15 mg/kg, an increasing percentage of the administered benzene was exhaled unmetabolized. Total metabolites per unit body weight were equal in rats and mice at doses up to 50 mg/kg/day. Total metabolites did not increase at higher doses in mice, suggesting saturation of metabolic pathways. Other studies similarly indicate that mice metabolize benzene more efficiently than rats (Medinsky et al. 1989a, 1989b; Travis et al. 1990).

Human and animal data show that exhalation is the main route for elimination of unmetabolized benzene, metabolites are excreted predominantly in the urine, and only a small amount of the absorbed amount is eliminated in feces (ATSDR 1997). Respiratory uptake (the amount of benzene absorbed from the lungs) and respiratory excretion (the amount of absorbed benzene excreted via the lungs) was approximately 47 and 17%, respectively, in six humans exposed to 52–62 ppm benzene for 4 hours (Nomiyama and Nomiyama 1974). Results from a study of 23 humans who inhaled 47–110 ppm benzene for 2–3 hours showed that 16.4–41.6 and 0.07–0.2% of the retained benzene was excreted in the breath (within 5–7 hours) and urine, respectively (Srbova et al. 1950). The major route of excretion following a 6-hour nose-only inhalation exposure of rats and mice to ^14^C-benzene appeared to be dependent on the inhaled concentration (Sabourin et al. 1987). At similar exposures to vapor concentrations of 10–1,000 ppm, the mice received 150–200% of the equivalent dose in rats on a per kg body weight basis. At all concentrations, fecal excretion accounted for <3.5 and <9% of the radioactivity in the rats and mice, respectively. At lower exposure concentrations (11–130 ppm), both rats and mice excreted <6% of the radioactivity in the expired air. At the highest exposure concentrations (870 ppm in rats, 990 ppm in mice), both rats and mice exhaled a significant amount of unmetabolized benzene (48 and 14%, respectively) following termination of exposure. The percentage of total excreted radioactivity that was not exhaled or associated with feces was 47–92% for rats and 80–94% for mice. Approximately 90% of the radioactivity was excreted as urinary metabolites by rats at ≤260 ppm and by mice at ≤130 ppm. The total urinary metabolite formation was 5–37% higher in the mice than in the rats at all doses, apparently due to the greater amount of benzene inhaled by mice per kg of body weight. The effect of dose on excretion of radioactivity was also studied in rats and mice following oral administration of 0.5–300 mg/kg single doses of ^14^C-benzene (Sabourin et al. 1987). At doses <15 mg/kg, ≥90% of the administered dose was excreted in the urine of both species. There was a linear relationship for the excretion of urinary metabolites up to 15 mg/kg; above that level, there was an increased amount of radioactivity in the expired air. Mice and rats excreted equal amounts up to 50 mg/kg; above this level, metabolism apparently became saturated in mice. Of a 150 mg/kg dose, 50 and 69% was eliminated in the expired air largely as unmetabolized benzene in rats and mice, respectively.

Four PBPK models have been developed to describe the behavior of benzene in rats, mice, and humans. The Medinsky model addresses species differences in benzene kinetics using rats and mice (Medinsky et al. 1989a, 1989b, 1989c). The Travis model specifically addresses human pharmacokinetics of benzene in comparison to experimental animal data (Travis et al. 1990), whereas the Bois and Paxman model (Bois and Paxman 1992) addresses the effect of exposure rate on benzene metabolism. The Sun model (Sun et al. 1990) addresses the formation of hemoglobin-benzene derived adducts in the blood, as a tool in monitoring benzene exposure.

## A.2 Health Effects

The nervous and hematopoietic systems are the main targets of benzene. Acute inhalation or oral exposure to high levels of benzene has caused symptoms and signs of central nervous system toxicity in humans and animals (ATSDR 1997; Carpenter et al. 1944; Cornish and Ryan 1965; Midzenski et al. 1992; Tauber 1970; Thienes and Haley 1972). Effects such as dizziness, vertigo, tremors, narcosis, and cardiac arrhythmias have been observed following both acute nonlethal and lethal exposures. Intermediate-duration inhalation and oral exposures to benzene induced neurological effects in animals that included reduced limb grip strength, behavioral disturbances, and changes in brain levels of monoamine transmitters and acetylcholinesterase (Dempster et al. 1984; Frantik et al. 1994; Hsieh et al. 1988; Li et al. 1992).

Hematotoxicity is the most noted and characteristic systemic effect resulting from intermediate and chronic benzene exposure in humans and animals. All of the major types of blood cells are susceptible (erythrocytes, leukocytes, and platelets). In the less severe cases of toxicity, specific deficiencies occur in individual types of blood elements. A common clinical finding is cytopenia, which is a decrease in various cellular elements manifested as anemia, leukopenia, or thrombocytopenia in humans (ATSDR 1997). Benzene-associated cytopenias vary and can involve a reduction in one (unicellular cytopenias) to all three (pancytopenia) cellular elements of the blood. Prolonged exposure to benzene can cause severe damage to the bone marrow involving cellular aplasia in humans and animals. This condition, known as aplastic anemia, is characterized by reduction of all cellular elements in the peripheral blood and in bone marrow (ATSDR 1997). Benzene-induced aplastic anemia can progress to AML, which is characterized by the appearance in the peripheral blood of cells morphologically indistinguishable from myeloblasts (Aksoy 1980; Aksoy et al. 1974; Doskin 1971; Rozen et al. 1984). Human studies that provide some estimate of levels of exposure indicate that adverse hematological effects occurred at levels >10 ppm and generally not at levels <1 ppm (ATSDR 1997). Adverse hematological effects begin to appear in animals at benzene concentrations of 10–100 ppm and above. Oral data are essentially limited to findings in intermediate- and chronic-duration animal studies showing that loss of blood elements occurs following exposure to benzene in drinking water or by gavage at doses as low as 8–25 mg/kg/day (ATSDR 1997).

Other health effects of benzene include immunological changes in humans and animals, which appear to be largely related to decreases in circulating leukocytes and the ability of lymphoid tissue to produce the mature lymphocytes necessary to form antibodies (ATSDR 1997). Adequate reproductive and developmental toxicity data on benzene are essentially limited to results of inhalation studies in animals (ATSDR 1997). There is suggestive evidence of benzene-induced testicular effects (e.g., atrophy/degeneration, decrease in spermatozoa, increase in abnormal sperm forms), particularly in mice following intermediate duration exposure to 300 ppm (ATSDR 1997; Ward et al. 1985; Wolf et al. 1956). Results of developmental toxicity studies indicate that inhalation exposure to high levels of benzene is fetotoxic and maternally toxic in several species as shown by decreased fetal weight and/or minor skeletal variants. Fetotoxic effects in rodents occurred at benzene levels ≥47 ppm (Coate et al. 1984; Green et al. 1978; Kuna and Kapp 1981; Murray et al. 1979; Tatrai et al. 1980a, 1980b; Ungvary and Tatrai 1985), although there was evidence of transient hematopoietic anomalies in fetuses and offspring of mice exposed to 5–20 ppm benzene (Keller and Snyder 1986, 1988). Chromosomal damage in bone marrow cells and lymphocytes are well documented effects of benzene based on findings in human occupational studies and in vivo studies in animals (ATSDR 1997). As indicated above, there is a well established causal relationship between occupational exposure to benzene and acute myelogenous leukemia (ATSDR 1997; Aksoy et al. 1971, 1972, 1974). Benzene-induced leukemia has not been clearly demonstrated in laboratory animals, although increased incidences of lymphomas, Zymbal gland carcinomas, and other neoplasms were found in rats and mice following chronic inhalation or oral exposure (ATSDR 1997; Cronkite et al. 1984, 1985, 1986, 1989; Farris et al. 1993; NTP 1986; Snyder et al. 1980, 1984, 1988).

## A.3 Mechanisms of Action

The most characteristic toxic effect of benzene is a decrease in bone marrow cellularity, which appears to ultimately lead to aplastic anemia and development of leukemia. The compensatory proliferative response (regenerative hyperplasia) to the anemia observed in the bone marrow, thymus, and spleen of exposed animals may play a role in the carcinogenic response (Rozen and Snyder 1985; Snyder 1987; Snyder and Koscis 1975; Snyder et al. 1984, 1993; Toft et al. 1982).

Metabolites appear to play key roles in the development of the hematotoxic, clastogenic, and carcinogenic effects of benzene. Studies of benzene metabolism and mechanisms of toxic action have identified or postulated a number of biologically reactive metabolites, including benzene oxide, benzene dihydrodiol, hydroquinone, catechol, benzoquinones, and muconaldehyde (ATSDR 1997). It is generally believed that benzene metabolites covalently bind to cellular macromolecules (including DNA, ribonucleic acid [RNA], and proteins), thereby leading to dysfunction in the bone marrow (including stem, progenitor, and stromal cells) and other tissues. For example, benzene and its metabolites may induce oxidative DNA damage or interfere with the incorporation of iron into bone marrow precursors (Longacre et al. 1981; Snyder and Kalf 1994; Snyder et al. 1989), chelates of iron and hydroquinone or 1,2,4-benzenetriol appear to be potent DNA cleaving agents (Rao 1996; Singh et al. 1994), and hydroquinone may accumulate in bone marrow to act as substrates for myeloperoxidase, forming benzoquinone which is myelotoxic and clastogenic (ATSDR 1997; Medinsky et al. 1994).

The relationship between adduct formation and toxicity is not clear, and multiple metabolic pathways and mechanisms are involved in benzene toxicity and carcinogenicity. The multiple metabolic pathways provide opportunities for modulation of benzene metabolism, either by competition with other chemicals for the available cytochrome P-450 sites, by induction or inhibition of the oxidation or conjugation enzymes, or by direct competition between benzene and its metabolites (Medinsky et al. 1994). There also may be synergism between metabolites (Eastmond et al. 1987; Snyder et al. 1989) or between glutathione-depleting metabolites of benzene and oxygen radicals (generated by futile cycling of cytochrome P-450 or cycling of quinone metabolites) (Parke 1989).

The acute neurological effects of benzene are similar to the general anesthetic effects of other lipophilic solvents, and consequently are presumed to result from a direct effect of the parent compound on central nervous system cell membranes unrelated to its metabolites (Snyder et al. 1993). There is a paucity of mechanistic information on the chronic nervous system toxicity of benzene (ATSDR 1997; Snyder et al. 1993).

## A.4 Health Guidelines

ATSDR (1997) derived an acute-duration inhalation MRL of 0.05 ppm for benzene based on a LOAEL of 10 ppm for immunotoxicity (reduced lymphocyte proliferation) following mitogen stimulation in mice (Rozen et al. 1984). The animal LOAEL was converted to a human equivalent concentration (LOAEL_HEC_) of 14.7 ppm and divided by an uncertainty factor of 300 (10 for the use of a LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability) to yield the MRL. The mice were exposed 6 hours/day for 6 days.

ATSDR (1997) derived an intermediate-duration inhalation MRL of 0.004 ppm for benzene based on a LOAEL of 0.78 ppm for neurological effects (increased rapid response time) in mice (Li et al. 1992). The animal LOAEL was converted to a LOAEL_HEC_ of 0.33 ppm and divided by an uncertainty factor of 90 (3 for the use of a minimal LOAEL, 3 for extrapolation from animals to humans, and 10 for human variability) to yield the MRL. The mice were exposed 6 hours/day, 6 days/week for 30 days.

ATSDR (1997) did not derive a chronic-duration inhalation MRL or acute-, intermediate-, or chronic-duration oral MRLs for benzene due to lack of suitable data.

The EPA Integrated Risk Information System (IRIS) database does not list a RfD or RfC for benzene (IRIS 2001). EPA has classified benzene as a “known” human carcinogen (Category A) under the 1986 Risk Assessment Guidelines (IRIS 2001). Under EPA’s proposed revised Carcinogen Risk Assessment Guidelines, benzene is characterized as a known human carcinogen for all routes of exposure based on convincing human evidence as well as supporting evidence from animal studies (IRIS 2001). Based on leukemia data in humans, an inhalation unit risk range of 2.2×10^−6^–7.8×10^−6^ per μg/m^3^ was estimated for benzene (IRIS 2001). The inhalation unit risk range was extrapolated to an oral (drinking water) unit risk range of 4.4×10^−4^–1.6×10^−3^ per mg/L (IRIS 2001).

The NTP (2001) concluded that benzene is known to be a human carcinogen. IARC (1987) classified benzene as a Group 1 carcinogen (carcinogenic to humans).

ACGIH (2001) recommends a TLV-TWA of 0.5 ppm and short-term exposure limit/ceiling (STEL/C) of 2.5 ppm for benzene based on cancer as the critical effect. ACGIH has included benzene in the carcinogenicity category A1 (confirmed human carcinogen).

## A.5 References

ACGIH. 2001. Threshold limit values for chemical substances and physical agents and biological exposure indices. Cincinnati, OH: American Conference of Governmental Industrial Hygienists.
Aksoy M. 1980. Different types of malignancies due to occupational exposure to benzene: A review of recent observations in Turkey. Environ Res 23:181–190. (As cited in ATSDR 1997.)7428756
Aksoy M, Dincol K, Akgun T, 1971. Haematological effects of chronic benzene poisoning in 217 workers. Br J Ind Med 28:296–302. (As cited in ATSDR 1997.)5557851
Aksoy M, Dincol K, Erdem S, 1972. Details of blood changes in 32 patients with pancytopenia associated with long-term exposure to benzene. Br J Ind Med 29:56–64. (As cited in ATSDR 1997.)5060246
Aksoy M, Erdem S, Dincol G. 1974. Leukemia in shoe-workers exposed chronically to benzene. Blood 44:837–841.4529630
Arinc E, Adaldi O, Iscan M, 1991. Stimulatory effects of benzene on rabbit liver and kidney microsomal cytochrome P-450 dependent drug metabolizing enzymes. Arch Toxicol 65(3):186–190. (As cited in ATSDR 1997.)2053845
ATSDR. 1997. Toxicological profile for benzene. Atlanta, GA: U.S. Department of Health and Human Services. Public Health Service, Agency for Toxic Substances and Disease Registry.
Bois FY, Paxman DG. 1992. An analysis of exposure rate effects for benzene using a physiologically based pharmacokinetic model. Regul Toxicol Pharmacol 110(1):79–88. (As cited in ATSDR 1997.)
Carpenter CP, Shaffer CB, Weil CS, 1944. Studies on the inhalation of 1:3-butadiene; with a comparison of its narcotic effect with benzol, toluol, and styrene, and a note on the elimination of styrene by the human. J Ind Hyg Toxicol 26:69–78. (As cited in ATSDR 1997.)
Coate WB, Hoberman AM, Durloo RS. 1984. Inhalation teratology study of benzene in rats. Adv Mod Environ Toxicol 6:187–198. (As cited in ATSDR 1997.)
Cornish HH, Ryan RC. 1965. Metabolism of benzene in nonfasted, fasted, and aryl-hydroxylase inhibited rats. Toxicol Appl Pharmacol 7:767–771. (As cited in ATSDR 1997.)5895051
Cronkite EP. 1986. Benzene hematotoxicity and leukemogenesis. Blood Cells 12:129–137. (As cited in ATSDR 1997.)3790732
Cronkite EP, Bullis JE, Inoue T, 1984. Benzene inhalation produces leukemia in mice. Toxicol Appl Pharmacol 75:358–361. (As cited in ATSDR 1997.)6474468
Cronkite EP, Drew RT, Inoue T, 1985. Benzene hematotoxicity and leukemogenesis. Am J Ind Med 7:447–456. (As cited in ATSDR 1997.)4003404
Cronkite EP, Drew RT, Inoue T, 1989. Hematotoxicity and carcinogenicity of inhaled benzene. Environ Health Perspect 82:97–108. (As cited in ATSDR 1997.)2792054
Dempster AM, Evans HL, Snyder CA. 1984. The temporal relationship between behavioral and hematological effects of inhaled benzene. Toxicol Appl Pharmacol 76:195–203. (As cited in ATSDR 1997.)6484989
Doskin VA. 1971. [Effect of age on the reaction to a combination of hydrocarbons.] Hyg Sanit 36:379–384. (Russian). (As cited in ATSDR 1997.)
Eastmond DA, Smith MT, Irons RD. 1987. An interaction of benzene metabolites reproduces the myelotoxicity observed with benzene exposure. Toxicol Appl Pharmacol 91:85–95.2823417
Eutermoser M, Rusch GM, Kuna RA, 1986. A method for repeated evaluation of benzene uptake in rats and mice during a six hour inhalation period. Am Ind Hyg Assoc J 47:37–40. (As cited in ATSDR 1997.)3946198
Farris GM, Everitt JI, Irons RD, 1993. Carcinogenicity of inhaled benzene in CBA mice. Fundam Appl Toxicol 20(4):503–507. (As cited in ATSDR 1997.)8314465
Frantik E, Hornychova M, Horvath M. 1994. Relative acute neurotoxicity of solvents: Isoeffective air concentrations of 48 compounds evaluated in rats and mice. Environ Res 66:173–185. (As cited in ATSDR 1997.)8055839
Franz TJ. 1984. Percutaneous absorption of benzene. In: MacFarland HN, Holdsworth CE, MacGregor JA, , eds. Advances in modern environmental toxicology. Vol. VI. Applied toxicology of petroleum hydrocarbons. Princeton, NJ: Princeton Scientific Publishers, Inc., 61–70. (As cited in ATSDR 1997.)
Ganousis LG, Goon D, Zyglewska T, 1992. Cell-specific metabolism in mouse bone marrow stroma: studies of activation and detoxification of benzene metabolites. Mol Pharmacol 42(6):1118–1125. (As cited in ATSDR 1997.)1480134
Gonasun LM, Witmer C, Kocsis J, 1973. Benzene metabolism in mouse liver microsomes. Toxicol Appl Pharmacol 26:398–406. (As cited in ATSDR 1997.)4148939
Green JD, Leong BKJ, Laskin S. 1978. Inhaled benzene fetotoxicity in rats. Toxicol Appl Pharmacol 46:9–18. Ganousis LG, Goon D, Zyglewska T, 1992. Cell-specific metabolism in mouse bone marrow stroma: studies of activation and detoxification of benzene metabolites. Mol Pharmacol 42(6):1118–1125. (As cited in ATSDR 1997.)
Gut I, Terelius Y, Frantík E, 1993. Exposure to various benzene derivatives differently induces cytochromes P450 2B1 and P450 2E1 in rat liver. Arch Toxicol 67:237–243.8517779
Hanke J, Dutkiewicz T, Piotrowski J. 1961. [The absorption of benzene through the skin in men]. Medycyna Pracy 12:413–426. (Polish). (As cited in ATSDR 1997.)
Henderson RF, Sabourin PJ, Bechtold WE, 1989. The effect of dose, dose rate, route of administration, and species on tissue and blood levels of benzene metabolites. Environ Health Perspect 82:9–17. (As cited in ATSDR 1997.)2792053
Hsieh GC, Parker RDR, Sharma RP. 1988. Subclinical effects of groundwater contaminants. II. Alteration of regional brain monoamine neurotransmitters by benzene in CD-1 mice. Arch Environ Contam Toxicol 17:799–805. (As cited in ATSDR 1997.)2906531
IARC. 1987. IARC monographs on the evaluation of carcinogenic risks to humans. Overall evaluations of carcinogenicity: An updating of IARC Monographs volumes 1 to 42. Suppl 7. Lyons, France: World Health Organization. International Agency for Research on Cancer, 38–74. (As cited in ATSDR 1997.)
IRIS. 2001. Benzene. Integrated Risk Information System, U.S. Environmental Protection Agency. http://www.epa.gov/iris/subst/0276.htm.
Irons RD, Dent JG, Baker TS, 1980. Benzene is metabolized and covalently bound in bone marrow in situ. Chem-Biol Interact 30:241–245. (As cited in ATSDR 1997.)7389002
Keller KA, Snyder CA. 1986. Mice exposed in utero to low concentrations of benzene exhibit enduring changes in their colony forming hematopoietic cells. Toxicology 42:171–181. (As cited in ATSDR 1997.)
Keller KA, Snyder CA. 1988. Mice exposed in utero to 20 ppm benzene exhibit altered numbers of recognizable hematopoietic cells up to seven weeks after exposure. Fundam Appl Toxicol 10:224–232. (As cited in ATSDR 1997.)3356309
Kuna RA, Kapp RW. 1981. Embryotoxic/teratogenic potential of benzene vapor in rats. Toxicol Appl Pharmacol 57:1–7. (As cited in ATSDR 1997.)7209981
Li L, Sun W, Gong Z, 1992. Effect of low benzene exposure on neurobehavioral function, AChE in blood and brain and bone marrow picture in mice. Biomed Environ Sci 5(4):349–354. (As cited in ATSDR 1997.)1489529
Longacre SL, Locsis JJ, Witmer CM, 1981. Toxicological and biochemical effects of repeated administration of benzene in mice. J Toxicol Environ Health 7:223–237. (As cited in ATSDR 1997.)7230271
Maibach HI, Anjo DM. 1981. Percutaneous penetration of benzene and benzene contained in solvents in the rubber industry. Arch Environ Health 36:256–260. (As cited in ATSDR 1997.)7294890
Medinsky MA, Sabourin PJ, Henderson RF, 1989a. Differences in the pathways for metabolism of benzene in rats and mice stimulated by a physiological model. Environ Health Perspect 82:43–49. (As cited in ATSDR 1997.)2792050
Medinsky MA, Sabourin PJ, Lucier G, 1989b. A physiological model for simulation of benzene metabolism by rats and mice. Toxicol Appl Pharmacol 99:193–206. (As cited in ATSDR 1997.)2734786
Medinsky MA, Sabourin PJ, Lucier G, 1989c. A toxicokinetic model for simulation of benzene metabolism. Exp Pathol 37:150–154. (As cited in ATSDR 1997.)2637146
Medinsky MA, Schlosser PM, Bond JA. 1994. Critical issues in benzene toxicity and metabolism: the effect of interactions with other organic chemicals on risk assessment. Environ Health Perspect 102(Suppl 9):119–124. (As cited in ATSDR 1997.)
Midzenski MA, McDiarmid MA, Rothman N, 1992. Acute high dose exposure to benzene in shipyard workers. Am J Ind Med 22:553–565. (As cited in ATSDR 1997.)1442788
Murray FJ, John JA, Rampy LW, 1979. Embryotoxicity of inhaled benzene in mice and rabbits. Am Ind Hyg Assoc J 40:933–998. (As cited in ATSDR 1997.)532779
Nakajima T, Wang RI, Elovaara E, 1993. Cytochrome P450-related differences between rats and mice in the metabolism of benzene toluene and trichloroethylene in liver microsomes. Biochem Pharmacol 45(5):1079–1085.8461037
Nomiyama K, Nomiyama H. 1974. Respiratory retention, uptake and excretion of organic solvents in man: Benzene, toluene, n-hexane, trichloroethylene, acetone, ethyl alcohol. Int Arch Arbeitsmed 32:75–83. (As cited in ATSDR 1997.)4813696
NTP. 1986. Toxicology and carcinogenesis studies of benzene (CAS No. 71–43-2) in F344/N rats and B6C3F_1_ mice (gavage studies). Research Triangle Park, NC: U.S. Department of Health and Human Services, Public Health Service, National Institute of Health. National Toxicology Program. NIH Publication no. 86–2545. Technical report series no. 289. (As cited in ATSDR 1997.)
NTP. 2001. Ninth report on carcinogens. U.S. Department of Health and Human Services, Public Health Service, National Toxicology Program. http://ehis.niehs.nih.gov/roc/toc9.html. June 2001.
Parke DV. 1989. Introduction: Session on metabolism. Environ Health Perspect 82:7–8. (As cited in ATSDR 1997.)
Parke DV, Williams RT. 1953a. Studies in detoxication. 49. The metabolism of benzene containing [^14^C_1_] benzene. Biochem J 54:231–238. (As cited in ATSDR 1997.)13058864
Parke DV, Williams RT. 1953b. Studies in detoxification 54. The metabolism of benzene. (a) The formation of phenylglucuronide & phenylsulphuric acid from [^14^C] benzene (b) the metabolism of [^14^C_1_] benzene. Biochem J 54: 231–238. (As cited in ATSDR 1997.)13058864
Pekari K, Vainiotalo S, Heikkila P, 1992. Biological monitoring of occupational exposure to low levels of benzene. Scand J Work Environ Health 18(5):317–322. (As cited in ATSDR 1997.)1439659
Rao GS. 1996. Glutathionyl hydroquinone: A potent pro-oxidant and a possible toxic metabolite of benzene. Toxicology 106:49–54. (As cited in ATSDR 1997.)8571401
Rozen MG, Snyder CA. 1985. Protracted exposure of C57BL/6 mice to 300 ppm benzene depresses B- and T-lymphocyte numbers and mitogen responses. Evidence for thymic and bone marrow proliferation in response to the exposures. Toxicology 37:13–26. (As cited in ATSDR 1997.)
Rozen MG, Snyder CA, Albert RE. 1984. Depression in B- and T-lymphocyte mitogen-induced blastogenesis in mice exposed to low concentrations of benzene. Toxicol Lett 20:343–349. (As cited in ATSDR 1997.)6608167
Sabourin PJ, Bechtold WE, Birnbaum LS, 1988. Differences in the metabolism and disposition of inhaled [^3^ H]benzene by F344/N rats and B6C3F_1_ mice. Toxicol Appl Pharmacol 94:128–140. (As cited in ATSDR 1997.)3376110
Sabourin PJ, Bechtold WE, Griffith WC, 1989a. Effect of exposure concentration, exposure rate, and route of administration on metabolism of benzene by F344 rats and B6C3F_1_ mice. Toxicol Appl Pharmacol 99:421–444. (As cited in ATSDR 1997.)2749731
Sabourin PJ, Chen BT, Lucier G, 1987. Effect of dose on the absorption and excretion of [14C]benzene administered orally or by inhalation in rats and mice. Toxicol Appl Pharmacol 87:325–336. (As cited in ATSDR 1997.)3824388
Sabourin PJ, Muggenburg BA, Couch RC, 1992. Metabolism of [^14^C]benzene by Cynomolgus monkeys and chimpanzees. Toxicol Appl Pharmacol 114(2):277–284. (As cited in ATSDR 1997.)1609420
Sabourin PJ, Sun JD, Birnbaum LS, 1989b. Effect of repeated benzene inhalation exposures on subsequent metabolism of benzene. Exp Pathol 37:155–157. (As cited in ATSDR 1997.)2637147
Saito FU, Kocsis JJ, Snyder R. 1973. Effect of benzene on hepatic drug metabolism and ultrastructure. Toxicol Appl Pharmacol 26:209–217. (As cited in ATSDR 1997.)4751099
Sato A, Nakajima T, Fujiwara Y, 1975. Kinetic studies on sex differences in susceptibility to chronic benzene intoxication- with special reference to body fat content. Br J Ind Med 32:321–328. (As cited in ATSDR 1997.)1103957
Schrenk D, Ingelman-Sundberg M, Bock KW. 1992. Influence of P-4502E1 induction on benzene metabolism in rat hepatocytes and on biliary metabolite excretion. Drug Metab Dispos 20(2):137–141. (As cited in ATSDR 1997.)1352201
Singh V, Ahmad S, Rao GS. 1994. Prooxidant and antioxidant properties of iron-hydroquinone and iron-1,2,4-benzenetriol complex. Implications for benzene toxicity. Toxicology 89(1):25–33. (As cited in ATSDR 1997.)7513907
Snyder CA. 1987. Benzene. In: Snyder R, ed. Ethyl Browning’s toxicity and metabolism of industrial solvents. 2^nd^ ed. Vol. 1: Hydrocarbons. (As cited in ATSDR 1997.)
Snyder CA, Goldstein BD, Sellakumar AR, 1980. The inhalation toxicology of benzene: Incidence of hematopoietic neoplasms and hematotoxicity in AKR/J and C57BL/6J mice. Toxicol Appl Pharmacol 54:323–331. (As cited in ATSDR 1997.)6893503
Snyder CA, Goldstein BD, Sellakumar AR. 1984. Evidence for hematotoxicity and tumorigenesis in rats exposed to 100 ppm benzene. Am J Ind Med 5:429–434. (As cited in ATSDR 1997.)6731444
Snyder CA, Sellakumar AR, James DJ, 1988. The carcinogenicity of discontinuous inhaled benzene exposures in CD-1 and C57BL/6 mice. Arch Toxicol 62:331–335. (As cited in ATSDR 1997.)3242441
Snyder R, Kalf GF. 1994. A perspective on benzene leukemogenesis. Crit Rev Toxicol 1994. 24(3):177–209. (As cited in ATSDR 1997.)
Snyder R, Kocsis JJ. 1975. Current concepts of chronic benzene toxicity. CRC Crit Rev Toxicol 3:265–288. (As cited in ATSDR 1997.)1097190
Snyder R, Dimitriadis E, Guy R, 1989. Studies on the mechanism of benzene toxicity. Environ Health Perspect 82:31–35.2792049
Snyder R, Witz G, Goldstein BD. 1993. The toxicology of benzene. Environ Health Perspect 100:293–306.8354177
Srbova J, Teisinger J, Skramovsky S. 1950. Absorption and elimination of inhaled benzene in man. Arch Ind Hyg Occup Med 2:1–8. (As cited in ATSDR 1997.)15433511
Sun JD, Medinsky MA, Birnbaum LS, 1990. Benzene hemoglobin adducts in mice and rats: Characterization of formation and physiological modeling. Fundam Appl Toxicol 15:468–475. (As cited in ATSDR 1997.)2258011
Susten A, Dames B, Burg J, 1985. Percutaneous penetration of benzene in hairless mice: An estimate of dermal absorption during tire-building operations. Am J Ind Med 7:323–335. (As cited in ATSDR 1997.)3993649
Tatrai E, Rodics K, Ungvary G. 1980a. Embryotoxic effects of simultaneously applied exposure of benzene and toluene. Folia Morphol (Praha) 28:286–289. (As cited in ATSDR 1997.)7409692
Tatrai E, Ungvary GY, Hudak A, 1980b. Concentration dependence of the embryotoxic effects of benzene inhalation in CFY rats. J Hyg Epidemiol Microbiol Immunol 24:363–371. (As cited in ATSDR 1997.)
Tauber J. 1970. Instant benzol death. J Occup Med 12:94–92. (As cited in ATSDR 1997.)
Thienes H, Haley TJ. 1972. Clinical toxicology. 5^th^ ed. Philadelphia, PA: Lea & Febiger, 124–127. (As cited in ATSDR 1997.)
Toft K, Olofsson T, Tunek A, 1982. Toxic effects on mouse bone marrow caused by inhalation of benzene. Arch Toxicol 51:295–302. (As cited in ATSDR 1997.)
Travis C, Bowers J. 1990. Altered pharmacokinetics of soil-absorbed benzene administered orally in the rat. Bull Environ Contam Toxicol 45(2):197–207. (As cited in ATSDR 1997.)2400835
Ungvary G, Tatrai E. 1985. On the embryotoxic effects of benzene and it’s alkyl derivatives in mice, rats and rabbits. Arch Toxicol Suppl 8:425–430. (As cited in ATSDR 1997.)3868373
Ward CO, Kuna RA, Snyder NK, 1985. Subchronic inhalation toxicity of benzene in rats and mice. Am J Ind Med 7:457–473. (As cited in ATSDR 1997.)4003405
Wolf MA, Rowe VK, McCollister DD, 1956. Toxicological studies of certain alkylated benzene and benzene. AMA Arch Ind Health 14:387–398. (As cited in ATSDR 1997.)13361560