# LIST OF ACRONYMS, ABBREVIATIONS, AND SYMBOLS

ACGIH: American Conference of Governmental Industrial Hygienist
AML: acute myelogenous leukemia
ATSDR: Agency for Toxic Substances and Disease Registry
AUC: areas under the blood concentration curves
B: benzene
BEI: biological exposure index
BHIs: biological hazard indexes
BINWOE: binaiy weight-of-evidence
BTEX: benzene, toluene, ethylbenzene, and xylenes
CERCLA: Comprehensive Environmental Response, Compensation, and Liability Act
CI: confidence interval
cm: centimeters
CYP: cytochrome P-450
DA: dopamine
DBTEX: dichloromethane, benzene, toluene, ethylbenzene, and xylenes
DNA: deoxyribonucleic acid
DOPAC: 3,4-dihydroxyphenylacetic acid
DT: Division of Toxicology
E: ethylbenzene
EC_50_: effective concentration, 50%
EPA: Environmental Protection Agency
FQPA: Food Quality Protection Act
HI: hazard index
5-HIAA: 5-hydroxyindoleacetic acid
5-HT: indoleamine serotonin
HVA: homovanillic acid
IARC: International Agency for Research on Cancer
IRIS: Integrated Risk Information System
kg: kilogram
L: liter
LOAEL: lowest-observed-adverse-effect level
LSE: Levels of Significant Exposure
m^3^: cubic meters
mg: milligram
mL: milliliter
mm: millimeter
MRI: magnetic resonance imagery
MRL: Minimal Risk Level
NADH: nicotinamide adenine dinucleotide phosphate (reduced form)
NADPH: nicotinamide adenine dinucleotide phosphate (oxidized form)
NE: norepiephrine
NOAEL: no-observed-adverse-effect level
NTP: National Toxicology Program
OPT: olfactory perception thr esholds
PBPK: physiologically based pharamacokinetic
ppm: parts per million
RD_50_: respiratory depression, 50%
RfC: reference concentration
RfD: reference dose
RNA: ribonucleic acid
SC: simulated concentration
SD: standard deviation
STEL: short-term exposure limit
T: toluene
TLV: threshold limit value
TTD: target-organ toxicity dose
TWA: time-weighted average
UDP: uridine-5'-diphosphate
μg: micrograms
μL: microliters
μmol: micromole
U.S.: United States
VMA: vanillylmanelic acid
X: xylenes
>: greater than
≥: greater than or equal to
=: equal to
<: less than
≤: less than or equal to